# References

1 Dimopoulos MA, Anagnostopoulos A, Weber D. Treatment of plasma cell dyscrasias with thalidomide and its derivatives. [Review]. Journal of Clinical Oncology. 2003;21(23):4444-4454. [pmid: 14645435].
2 Kyle RA. Clinical and laboratory manifestations of multiple myeloma. Up-to-date [www.uptodate.com]. Accessed July 15, 2005.
3 International Myeloma Working Group. Criteria for the classification of monoclonal gammopathies, multiple myeloma and related disorders: a report of the International Myeloma Working Group. British Journal of Haematology. Jun. 2003;121(5):749-757. [pmid: 12780789].
4 American Cancer Society. Cancer Facts and Figures 2005. 2005. http://www.cancer.org/docroot/STT/stt_0.asp. Accessed March 25, 2005.
5 Lynch HT, Watson P, Tarantolo S, et al. Phenotypic Heterogeneity in Multiple Myeloma Families. Journal of Clinical Oncology. February. 1. 2005;23(4):685-693. [pmid: 15681516].
6 Kyle RA. "Benign" monoclonal gammopathy―after 20 to 35 years of follow-up. Mayo Clinic Proceedings. Jan. 1993;68(1):26-36. [pmid: 8417251].
7 Grethlein S. Multiple myeloma. eMedicine [http://www.emedicine.com/med/topic1521.htm. Accessed July 16, 2005.
8 Kyle RA, Rajkumar SV. Multiple myeloma.[see comment][erratum appears in N Engl J Med. 2005 Mar 17;352(11):1163]. New England Journal of Medicine. Oct. 28. 2004;351(18):1860-1873. [pmid: 15509819].
9 Kyle R. Dollinger M, Rosenbaum E, Cable G, editors. Multiple myeloma. Everybody’s Guide to Cancer Therapy. 1997:592-599.
10 Kyle RA. Diagnosis and differential diagnosis of multiple myeloma. Up-to-date [www.uptodate.com]. Accessed July 15, 2005.
11 Greipp PR. Smoldering, asymptomatic stage 1, and indolent myeloma. [Review]. Current Treatment Options in Oncology. 2000;1(2):119-126. [pmid: 12057049].
12 National Cancer Institute. Multiple Myeloma and Other Plasma Cell Neoplasms (PDQ®): Treatment. http://www.cancer.gov/cancertopics/pdq/treatment/CML/HealthProfessional/page4#Reference4.32. Accessed July 15, 2005.
13 Durie BG, Salmon SE. A clinical staging system for multiple myeloma. Correlation of measured myeloma cell mass with presenting clinical features, response to treatment, and survival. Cancer. Sep. 1975;36(3):842-854. [pmid: 1182674].
14 Greipp PR, San Miguel J, Durie BG, et al. International staging system for multiple myeloma. Journal of Clinical Oncology. May. 20. 2005;23(15):3412-3420. [pmid: 15809451].
15 Durie BG, Stock-Novack D, Salmon SE, et al. Prognostic value of pretreatment serum beta 2 microglobulin in myeloma: a Southwest Oncology Group Study.[see comment]. Blood. Feb. 15. 1990;75(4):823-830. [pmid: 2405920].
16 American Cancer Society. How is multiple myeloma treated?. 2005. http://www.cancer.org/docroot/STT/stt_0.asp. Accessed July 15, 2005.
17 Blade J, Samson D, Reece D, et al. Criteria for evaluating disease response and progression in patients with multiple myeloma treated by high-dose therapy and haemopoietic stem cell transplantation. Myeloma Subcommittee of the EBMT. European Group for Blood and Marrow Transplant. British Journal of Haematology. Sep. 1998;102(5):1115-1123. [pmid: 9753033].
18 Kyle RA, Gertz MA, Witzig TE, et al. Review of 1027 patients with newly diagnosed multiple myeloma.[see comment]. Mayo Clinic Proceedings. Jan. 2003;78(1):21-33. [pmid: 12528874].
19 Fonseca R, Blood E, Rue M, et al. Clinical and biologic implications of recurrent genomic aberrations in myeloma. Blood. Jun. 1. 2003;101(11):4569-4575. [pmid: 12576322].
20 Kumar S, Fonseca R, Dispenzieri A, et al. Bone marrow angiogenesis in multiple myeloma: effect of therapy. British Journal of Haematology. Dec. 2002;119(3):665-671. [pmid: 12437642].
21 Lee CK, Barlogie B, Munshi N, et al. DTPACE: an effective, novel combination chemotherapy with thalidomide for previously treated patients with myeloma. Journal of Clinical Oncology. 2003;21(14):2732-2739. [pmid: 12860952].
22 Riccardi A, Mora O, Tinelli C, et al. Long-term survival of stage I multiple myeloma given chemotherapy just after diagnosis or at progression of the disease: a multicentre randomized study. Cooperative Group of Study and Treatment of Multiple Myeloma. British Journal of Cancer. Apr. 2000;82(7):1254-1260. [pmid: 10755397].
23 He Y, Wheatley K, Clark O, et al. Early versus deferred treatment for early stage multiple myeloma. Cochrane Database of Systematic Reviews. 2003;(1):CD004023. [pmid: 12535504].
24 Myeloma Trialists' Collaborative Group. Combination chemotherapy versus melphalan plus prednisone as treatment for multiple myeloma: an overview of 6,633 patients from 27 randomized trials. Journal of Clinical Oncology. Dec. 1998;16(12):3832-3842. [pmid: 9850028].
25 Oken MM, Harrington DP, Abramson N, et al. Comparison of melphalan and prednisone with vincristine, carmustine, melphalan, cyclophosphamide, and prednisone in the treatment of multiple myeloma: results of Eastern Cooperative Oncology Group Study E2479. Cancer. Apr. 15. 1997;79(8):1561-1567. [pmid: 9118039].
26 Kildahl-Andersen O, Bjark P, Bondevik A, et al. Multiple myeloma in central and northern Norway 1981–1982: a follow-up study of a randomized clinical trial of 5-drug combination therapy versus standard therapy. European Journal of Haematology. Jul. 1988;41(1):47-51. [pmid: 3042453].
27 Kildahl-Andersen O, Bjark P, Bondevik A, et al. Multiple myeloma in central Norway 1981–1982: a randomized clinical trial of 5-drug combination therapy versus standard therapy. Scandinavian Journal of Haematology. Sep. 1986;37(3):243-248. [pmid: 3538367].
28 Hansen OP, Clausen NA, Drivsholm A, et al. Phase III study of intermittent 5-drug regimen (VBCMP) versus intermittent 3-drug regimen (VMP) versus intermittent melphalan and prednisone (MP) in myelomatosis. Scandinavian Journal of Haematology. Nov. 1985;35(5):518-524. [pmid: 3911373].
29 Barlogie B, Smith L, Alexanian R. Effective treatment of advanced multiple myeloma refractory to alkylating agents. New England Journal of Medicine. May. 24. 1984;310(21):1353-1356. [pmid: 6546971].
30 Samson D, Gaminara E, Newland A, et al. Infusion of vincristine and doxorubicin with oral dexamethasone as first-line therapy for multiple myeloma.[see comment]. Lancet. Oct. 14. 1989;2(8668):882-885. [pmid: 2571813].
31 Anderson H, Scarffe JH, Ranson M, et al. VAD chemotherapy as remission induction for multiple myeloma. British Journal of Cancer. Feb. 1995;71(2):326-330. [pmid: 7841049].
32 Segeren CM, Sonneveld P, van der Holt B, et al. Vincristine, doxorubicin and dexamethasone (VAD) administered as rapid intravenous infusion for first-line treatment in untreated multiple myeloma. British Journal of Haematology. Apr. 1999;105(1):127-130. [pmid: 10233375].
33 Mineur P, Menard JF, Le Loet X, et al. VAD or VMBCP in multiple myeloma refractory to or relapsing after cyclophosphamide-prednisone therapy (protocol MY 85). British Journal of Haematology. Nov. 1998;103(2):512-517. [pmid: 9827927].
34 Dimopoulos MA, Pouli A, Zervas K, et al. Prospective randomized comparison of vincristine, doxorubicin and dexamethasone (VAD) administered as intravenous bolus injection and VAD with liposomal doxorubicin as first-line treatment in multiple myeloma. Annals of Oncology. Jul. 2003;14(7):1039-1044. [pmid: 12853344].
35 Singhal S, Mehta J, Desikan R, et al. Antitumor activity of thalidomide in refractory multiple myeloma. [erratum appears in N Engl J Med 2000 Feb 3;342(5)364]. New England Journal of Medicine. 1999;341(21):1565-1571. [pmid: 10564685].
36 Lentzsch S, Rogers MS, LeBlanc R, et al. S-3-Amino-phthalimido-glutarimide inhibits angiogenesis and growth of B-cell neoplasias in mice. Cancer Research. 2002;62(8):2300-2305. [pmid: 11956087].
37 Olson K, Hall T, Horton J, et al. Thalidomide (N-phthaloylglutamimide) in the treatment of advanced cancer. Clinical Pharmacology and Therapeutics. 1965;6:292-297. [pmid: 14296025].
38 Eriksson T, Bjorkman S, Hoglund P. Clinical pharmacology of thalidomide. European Journal of Clinical Pharmacology. Aug. 2001;57(5):365-376. [pmid: 11599654].
39 Ramos J. Thalidomide: Price increases for cancer treatment. http://www.essentialdrugs.org/edrug/archive/200508/msg00053.php. Accessed Aug 26, 2005.
40 National Institute for Clinical Excellence. Gefitinib for non-small cell lung cancer - appraisal (project). London. National Institute for Clinical Excellence.
41 Rajkumar SV, Dispenzieri A, Fonseca R, et al. Thalidomide for previously untreated indolent or smoldering multiple myeloma. Leukemia. 2001;15(8):1274-1276. [pmid: 11480571].
42 Rajkumar SV, Gertz MA, Lacy MQ, et al. Thalidomide as initial therapy for early-stage myeloma. Leukemia. 2003;17(4):775-779. [pmid: 12682636].
43 Barlogie B, Desikan R, Eddlemon P, et al. Extended survival in advanced and refractory multiple myeloma after single-agent thalidomide: identification of prognostic factors in a phase 2 study of 169 patients. Blood. 2001;98(2):492-494. [pmid: 11435324].
44 Corso A, Lorenzi A, Orlandi E, Astori C, Mangiacavalli S, Lazzarino M. Advantages of using thalidomide for the management of refractory myeloma patients. Haematologica. 2002;87(3):328-328. [pmid: 11869950].
45 Hattori Y, Kakimoto T, Okamoto S, et al. Thalidomide-induced severe neutropenia during treatment of multiple myeloma. International Journal of Hematology. 2004;79(3):283-288. [pmid: 15168599].
46 Hus M, Dmoszynska A, Soroka-Wojtaszko M, et al. Thalidomide treatment of resistant or relapsed multiple myeloma patients. Haematologica. 2001;86(4):404-408. [pmid: 11325647].
47 Johnston RE, Abdalla SH. Thalidomide in low doses is effective for the treatment of resistant or relapsed multiple myeloma and for plasma cell leukaemia. Leukemia & Lymphoma. 2002;43(2):351-354. [pmid: 11999568].
48 Juliusson G, Celsing F, Turesson I. Frequent good partial remissions from thalidomide including best response ever in patients with advanced refractory and relapsed myeloma.[see comment]. British Journal of Haematology. Apr. 2000;109(1):89-96. [pmid: 10848786].
49 Kees M, Dimou G, Sillaber C, et al. Low dose thalidomide in patients with relapsed or refractory multiple myeloma. Leukemia & Lymphoma. 2003;44(11):1943-1946. [pmid: 14738147].
50 Kroeger N, Shimoni A, Zagrivnaja M, et al. Low dose thalidomide and donor lymphocyte infusion as adoptive immunotherapy after allogeneic stem cell transplantation in patients with multiple myeloma. Blood. 2004;104(11). Abstract #1646.
51 Kumar S, Gertz MA, Dispenzieri A, et al. Response rate, durability of response, and survival after thalidomide therapy for relapsed multiple myeloma. Mayo Clinic Proceedings. 2003;78(1):34-39. [pmid: 12528875].
52 Neben K, Moehler T, Egerer G, et al. High plasma basic fibroblast growth factor concentration is associated with response to thalidomide in progressive multiple myeloma. Clinical Cancer Research. 2001;7(9):2675-2681. [pmid: 11555579].
53 Rajkumar SV, Fonseca R, Dispenzieri A, et al. Thalidomide in the treatment of relapsed multiple myeloma. Mayo Clinic Proceedings. 2000;75(9):897-901. [pmid: 10994824].
54 Richardson P, Schlossman R, Jagannath S, et al. Thalidomide for patients with relapsed multiple myeloma after high-dose chemotherapy and stem cell transplantation: results of an open-label multicenter phase 2 study of efficacy, toxicity, and biological activity. Mayo Clinic Proceedings. 2004;79(7):875-882. [pmid: 15244383].
55 Schey SA, Cavenagh J, Johnson R, et al. An UK myeloma forum phase II study of thalidomide; long term follow-up and recommendations for treatment. Leukemia Research. 2003;27(10):909-914. [pmid: 12860011].
56 Tosi P, Ronconi S, Zamagni E, et al. Salvage therapy with thalidomide in multiple myeloma patients relapsing after autologous peripheral blood stem cell transplantation. Haematologica. 2001;86(4):409-413. [pmid: 11325648].
57 Tosi P, Zamagni E, Cellini C, et al. Salvage therapy with thalidomide in patients with advanced relapsed/refractory multiple myeloma. Haematologica. 2002;87(4):408-414. [pmid: 11940485].
58 Waage A, Gimsing P, Juliusson G, et al. Early response predicts thalidomide efficiency in patients with advanced multiple myeloma. British Journal of Haematology. 2004;125(2):149-155. [pmid: 15059136].
59 Yakoub-Agha I, Moreau P, Leyvraz S, et al. Thalidomide in patients with advanced multiple myeloma. Hematology Journal. 2000;1(3):186-189. [pmid: 11920188].
60 Yakoub-Agha I, Attal M, Dumontet C, et al. Thalidomide in patients with advanced multiple myeloma: a study of 83 patients―report of the Intergroupe Francophone du Myelome (IFM). Hematology Journal. 2002;3(4):185-192. [pmid: 12189564].
61 Rajkumar SV, Blood E, Vesole DH, et al. Thalidomide plus dexamethasone versus dexamethasone alone in newly diagnosed multiple myeloma (E1A00): Results of a phase III trial coordinated by the Eastern Cooperative Oncology Group. Blood. 2004;104(11). Abstract #205.
62 Rajkumar SV, Blood E, Vesole DH, et al. A randomised phase III trial of thalidomide plus dexamethasone versus dexamethasone in newly diagnosed multiple myeloma (E1A00): A trial coordinated by the Eastern Cooperative Oncology Group. Journal of Clinical Oncology 2004 ASCO Annual Meeting Proceedings (Post-Meeting Edition). 2004;22(14S). Abstract #6508.
63 Ludwig H, Drach J, Tóthová E, et al. Thalidomide-Dexamethason versus Melphalan- Prednisolone as first line treatment in elderly patients with multiple myeloma: an interim analysis. 2005 ASCO Annual Meeting. 2005. Abstract #6537.
64 Alexanian R, Weber D, Anagnostopoulos A, et al. Thalidomide with or without dexamethasone for refractory or relapsing multiple myeloma. [Review]. Seminars in Hematology. 2003;40(4 Suppl 4):3-7. [pmid: 15015890].
65 Rajkumar SV, Hayman S, Gertz MA, et al. Combination therapy with thalidomide plus dexamethasone for newly diagnosed myeloma. Journal of Clinical Oncology. 2002;20(21):4319-4323. [pmid: 12409330].
66 Rajkumar SV, Dingli D, Nowakowski G, et al. Thalidomide and Dexamethasone in newly diagnosed multiple myeloma: long-term results in patients not undergoing upfront autologous stem cell transplantation. 2005 ASCO Annual Meetings. 2005. Abstract #6632.
67 Weber D, Rankin K, Gavino M, et al. Thalidomide alone or with dexamethasone for previously untreated multiple myeloma. Journal of Clinical Oncology. 2003;21(1):16-19. [pmid: 12506164].
68 Anagnostopoulos A, Weber D, Rankin K, et al. Thalidomide and dexamethasone for resistant multiple myeloma. British Journal of Haematology. Jun. 2003;121(5):768-771. [pmid: 12780791].
69 Bernardeschi P, Dentico P, Rossi S, et al. Chemoresistant myeloma: phase II clinical study with low-dose thalidomide plus high-dose dexamethasone. Journal of Chemotherapy. Nov. Suppl 5. 2004;16:90-93. [pmid: 15675489].
70 Dimopoulos MA, Zervas K, Kouvatseas G, et al. Thalidomide and dexamethasone combination for refractory multiple myeloma. Annals of Oncology. 2001;12(7):991-995. [pmid: 11521808].
71 Myers B, Crouch D, Dolan G. Thalidomide treatment in advanced refractory myeloma.[see comment][comment]. British Journal of Haematology. Dec. 2000;111(3):986. [pmid: 11122165].
72 Myers B, Grimley C, Dolan G. Thalidomide and low-dose dexamethasone in myeloma treatment.[comment]. British Journal of Haematology. Jul. 2001;114(1):245. [pmid: 11472379].
73 Myers B, Dolan G. Analysis of durability of response to thalidomide treatment for relapsed myeloma patients. British Journal of Haematology. 2002;118(1):347. [pmid: 12100175].
74 Palumbo A, Giaccone L, Bertola A, et al. Low-dose thalidomide plus dexamethasone is an effective salvage therapy for advanced myeloma. Haematologica. 2001;86(4):399-403. [pmid: 11325646].
75 Palumbo A, Bertola A, Falco P, et al. Efficacy of low-dose thalidomide and dexamethasone as first salvage regimen in multiple myeloma. Hematology Journal. 2004;5(4):318-324. [pmid: 15297848].
76 Reece DE, Chen C, Trudel S, et al. Thalidomide +/- corticosteroids for the treatment of multiple myeloma patients > 70 years of age. Blood. 2004;104(11). Abstract #4934.
77 Tosi P, Zamagni E, Cellini C, et al. Thalidomide-induced peropheral neuropathy in newly diagnosed and pre-treated multiple myeloma patients. Blood. 2004;104(11). Abstract #4898.
78 Facon T, Mary JY, Hulin C, et al. Randomized clinical trial comparing melphalan-prednisone (MP), MP-thalidomide (MP-THAL) and high-dose therapy using melphalan 100 MG/M2 (MEL100) for newly diagnosed myeloma patients aged 65–75 years. Interim analysis of the IFM 99-06 trial on 350 patients. Blood. 2004;104(11). Abstract #206.
79 Palumbo A, Bertola A, Musto P, et al. A prospective randomized trial of oral melphalan, prednisone, thalidomide (MPT) vs. oral melphalan, prednisone (MP): an interim analysis. Blood. 2004;104(11). Abstract #207.
80 Alexanian R, Wang LM, Weber DM, et al. VTD (Velcade, Thalidomide, Dexamethasone) as primary therapy for newly-diagnosed multiple myeloma. Blood. 2004;104(11). Abstract #210.
81 Chanan-Khan AA, Miller KC, McCarthy P, et al. VAD-t (Vincristine, Adriamycin, Dexamethasone and Low-Dose Thalidomide) is an effective initial therapy with high response rates for patients with treatment naïve multiple myeloma (MM). Blood. 2004;104(11). Abstract #3463.
82 Dimopoulos MA, Repoussis P, Terpos E, et al. Primary treatment with pulsed melphalan, dexamethasone, thalidomide (MDT) for symptomatic patients with multiple myeloma >75 years of age. Blood. 2004;104(11). Abstract #1482.
83 Hassoun H, Reich L, Klimek VM, et al. Doxorubicin and dexamethasone followed by thalidomide and dexamethasone (AD-TD) as initial therapy for symptomatic patients with multiple myeloma. Blood. 2004;104(11). Abstract #2409.
84 Klueppelberg U, Smith E, Chen L, et al. First-line treatment of multiple myeloma with a combination of thalidomide, dexamethasone, and zoledronate (TDZ) in an inner-city population with high hiv prevalence. Blood. 2004;104(11). Abstract #4932.
85 Klueppelberg U, Chen L, Aloba CM, et al. First-line, long-term treatment of multiple myeloma with thalidomide, dexamethasone, and zoledronate in combination (TDZ). Journal of Clinical Oncology, 2004 ASCO Annual Meeting Proceedings (Post-Meeting Edition). 2004;22(14S). Abstract #6702.
86 Klueppelberg U, Shapira I, Chen L, et al. Long-term treatment of newly-diagnosed multiple myeloma with low-dose thalidomide, dexamethasone and zoledronate (TDZ). 2005 ASCO Annual Meeting. 2005. Abstract # 6697.
87 Schutt P, Ebeling P, Buttkereit U, et al. Thalidomide in combination with vincristine, epirubicin and dexamethasone (VED) for previously untreated patients with multiple myeloma. European Journal of Haematology. Jan. 2005;74(1):40-46. [pmid: 15613105].
88 Zervas K, Dimopoulos MA, Hatzicharissi E, et al. Primary treatment of multiple myeloma with thalidomide, vincristine, liposomal doxorubicin and dexamethasone (T-VAD doxil): a phase II multicenter study. Annals of Oncology. 2004;15(1):134-138. %O (139) English. [pmid: 14679133].
89 Badros AZ, Goloubeva O, Ratterree B, et al. Phase II trial of oblimersen sodium (G3139), dexamethasone (Dex) and thalidomide (Thal) in relapsed multiple myeloma patients (Pts). Blood. 2004;104(11). Abstract #2400.
90 Bibas M, Andriani A, Viva F, et al. Intermittent low doses of thalidomide in the maintenance treatment of multiple myeloma. Blood. 2004;104(11). Abstract #4927.
91 Chanan-Khan AA, Miller KC, McCarthy P, et al. A phase II study of velcade (V), doxil (D) in combination with low-dose thalidomide (T) as salvage therapy for patients (pts) with relapsed (rel) or refractory (ref) multiple myeloma (MM) and Waldenstorm Macroglobulinemia (WM): encouraging preliminary results. Blood. 2004;104(11). Abstract #2421.
92 Biagi JJ, Mileshkin L, Grigg AP, et al. Efficacy of thalidomide therapy for extramedullary relapse of myeloma following allogeneic transplantation. Bone Marrow Transplantation. 2001;28(12):1145-1150. [pmid: 11803357].
93 Ciepluch H, Baran W, Hellmann A. Combination of pamidronate and thalidomide in the therapy of treatment-resistant multiple myeloma. Medical Science Monitor. 2002;8(4):P131-P136.
94 Dimopoulos MA, Hamilos G, Zomas A, et al. Pulsed cyclophosphamide, thalidomide and dexamethasone: an oral regimen for previously treated patients with multiple myeloma. Hematology Journal. 2004;5(2):112-117. [pmid: 15048060].
95 Garcia-Sanz R, Gonzalez-Porras JR, Hernandez JM, et al. The oral combination of thalidomide, cyclophosphamide and dexamethasone (ThaCyDex) is effective in relapsed/refractory multiple myeloma. Leukemia. 2004;18(4):856-863. [pmid: 14973508].
96 Hollmig K, Stover J, Talamo G, et al. Bortezomib (Velcade™) + Adriamycin™ + Thalidomide + Dexamethasone (VATD) as an effective regimen in patients with refractory or relapsed multiple myeloma (MM). Blood. 2004;104(11). Abstract #2399.
97 Kasper B, Moehler T, Neben K, et al. Combination therapy of Thalidomide and Peginterferon in patients with progressive multiple myeloma. Annals of Oncology. Jan. 2004;15(1):176-177. [pmid: 14679142].
98 Kropff MH, Lang N, Bisping G, et al. Hyperfractionated cyclophosphamide in combination with pulsed dexamethasone and thalidomide (HyperCDT) in primary refractory or relapsed multiple myeloma. British Journal of Haematology. 2003;122(4):607-616. [pmid: 12899716].
99 Mileshkin L, Biagi JJ, Mitchell P, et al. Multicenter phase 2 trial of thalidomide in relapsed/refractory multiple myeloma: adverse prognostic impact of advanced age. Blood. 2003;102(1):69-77. [pmid: 12637329].
100 Mileshkin LR, Roberts A, Ganju V, et al. Quality of life (QOL) assessment in patients with relapsed/refractory multiple myeloma (MM) treated with thalidomide (T) plus celecoxib (Cxb). 2005 ASCO Annual Meeting. 2005. Abstract #8233.
101 Offidani M, Corvatta L, Marconi M, et al. Common and rare side-effects of low-dose thalidomide in multiple myeloma: focus on the dose-minimizing peripheral neuropathy. European Journal of Haematology. 2004;72(6):403-409. [pmid: 15128418].
102 Offidani M, Corvatta L, Marconi M, et al. Thalidomide plus oral melphalan compared with thalidomide alone for advanced multiple myeloma. Hematology Journal. 2004;5(4):312-317. [pmid: 15297847].
103 Suvannasankha A, Fausel C, Juliar BE, et al. Final report of a phase II study of oral cyclophosphamide, thalidomide, and prednisone (CTP) for patients with relapsed or refractory multiple myeloma: a Hoosier Oncology Group Trial: HEM01-21. 2005 ASCO Annual Meeting. 2005. Abstract #6591.
104 Teoh G, Hwang W, Koh LP, et al. Low dose dexamethasone and thalidomide with higher frequency zoledronic acid (dtZ) for multiple myeloma. Blood. 2004;104(1). Abstract #4915.
105 Williams CD, Byrne JL, Sidra G, et al. Combination chemotherapy with cyclophosphamide, thalidomide and dexamethasone achieves a high response rate in patients with newly diagnosed, VAD-refractory and relapsed myeloma. Blood. 2004;104(11). Abstract #1499.
106 Williams CC, Haura EB, Antonia SJ, et al. Phase II trial of docetaxel and gefitinib as first-line therapy for elderly patients with advanced nonsmall ell lung cancer (ANSCLC). Journal of Clinical Oncology, 2004 ASCO Annual Meeting Proceedings (Post-Meeting Edition). 2004;22(14S (July 15 Supplement)):7342.
107 Zangari M, Barlogie B, Hollmig K, et al. Marked activity of velcade plus thalidomide (V+T) in advanced and refractory multiple myeloma (MM). Blood. 2004;104(11). Abstract #1480.
108 Attal M, Harousseau JL, Leyvraz S, et al. Maintenance treatment with thalidomide after autologous transplantation for myeloma: first analysis of a prospective randomized study of the Intergroupe Francophone du Myelome (IFM 99 02). Blood. 2004;104(11). Abstract #535.
109 Barlogie B Jr, Shaughnessy JD. Early results of total therapy II in multiple myeloma: implications of cytogenetics and FISH. International Journal of Hematology. 2002;76(Suppl 1):337-339. [pmid: 12430877].
110 Barlogie B, Rasmussen E, Tricot G, et al. Management of patients with multiple myeloma (MM) failing total therapy 2 (TT 2) according to thalidomide (THAL) randomization. Blood. 2004;104(11). Abstract #1483.
111 Alexanian R, Weber D, Giralt S, et al. Consolidation therapy of multiple myeloma with thalidomide-dexamethasone after intensive chemotherapy. Annals of Oncology. 2002;13(7):1116-1119. [pmid: 12176792].
112 Sengar M, Kumar L, Ganessan K, et al. Role of post transplant maintenance therapy in multiple myeloma: results from a developing country. 2005 ASCO Annual Meeting. 2005. Abstract #6731.
113 Stewart AK, Chen C, Howson-Jan K, et al. Results of a multi-center randomized phase II trial of thalidomide and prednisone maintenance therapy for multiple myeloma following autologous stem cell transplant. Blood. 2004;104(11). Abstract #335.
114 Anaissie EJ, Talamo G, Angtuaco E, et al. Avascular necrosis of bone after therapy for multiple myeloma: a study of 561 consecutive patients. Blood. 2004;104(11). Abstract#3467.
115 Badros AZ, Siegel E, Bodenner D, et al. Hypothyroidism in patients with multiple myeloma following treatment with thalidomide. American Journal of Medicine. 2002;112(5):412-413. %O (439) English. [pmid: 11904117].
116 Bowcock SJ, Rassam SM, Ward SM. Thromboembolism in patients on thalidomide for myeloma. Hematology. 2002;7(1):51-53. [pmid: 12171777].
117 Fahdi IE, Gaddam V, Saucedo JF, et al. Bradycardia during therapy for multiple myeloma with thalidomide. American Journal of Cardiology. 2004;93(8):1052-1055. [pmid: 15081457].
118 Hall VC, El-Azhary RA, Bouwhuis S. Dermatologic side effects of thalidomide in patients with multiple myeloma. Journal of the American Academy of Dermatology. 2003;48(4):548-552. [pmid: 12664018].
119 Singh V, Klinge A, Luminari S, et al. Understanding thalidomide-associated deep vein thrombosis/pulmonary emboli (DVT/PE): comparison of quality and information included in adverse event reports from clinical trials, clinical practice, STEPS, and the medical literature. Journal of Clinical Oncology, 2004 ASCO Annual Meeting Proceedings (Post-Meeting Edition). 2004;22(14S). Abstract #3142.
120 Spencer A, Roberts A, Neeman T, et al. Renal safety evaluation of zoledronic acid and thalidomide when used as post-stem cell transplant maintenance therapy in multiple myeloma. Journal of Clinical Oncology, 2004 ASCO Annual Meeting Proceedings (Post-Meeting Edition). 2004;22(14S). Abstract #6655.
121 Tosi P, Zamagni E, Cellini C, et al. Neurological toxicity of long-term (>1 yr) thalidomide therapy in patients with multiple myeloma. European Journal of Haematology. Mar. 2005;74(3):212-216. [pmid: 15693790].
122 Zangari M, Anaissie E, Barlogie B, et al. Increased risk of deep-vein thrombosis in patients with multiple myeloma receiving thalidomide and chemotherapy. Blood. 2001;98(5):1614-1615. [pmid: 11520815].
123 Zangari M, Saghafifar F, Anaissie E, et al. Activated protein C resistance in the absence of factor V Leiden mutation is a common finding in multiple myeloma and is associated with an increased risk of thrombotic complications. Blood Coagulation & Fibrinolysis. 2002;13(3):187-192. [pmid: 11943931].
124 Zangari M, Siegel E, Barlogie B, et al. Thrombogenic activity of doxorubicin in myeloma patients receiving thalidomide: implications for therapy. Blood. 2002;100(4):1168-1171. [pmid: 12149193].
125 Zangari M, Barlogie B, Lee CK, et al. Protective effect of VELCADE® on thalidomide-associated deep vein thrombosis (DVT). Blood. 2004;104(11). Abstract #4914.
126 Zangari M, Barlogie B, Anaissie E, et al. Deep vein thrombosis in patients with multiple myeloma treated with thalidomide and chemotherapy: effects of prophylactic and therapeutic anticoagulation. British Journal of Haematology. Sep. 2004;126(5):715-721. [pmid: 15327525].
127 Mileshkin L, Prince HM, Seymour JF, et al. Serum MUC-1 as a marker of disease status in multiple myeloma patients receiving thalidomide. British Journal of Haematology. 2003;123(4):747-748. [pmid: 14616984].
128 Dmoszynska A, Bojarska-Junak A, Domanski D, et al. Production of proangiogenic cytokines during thalidomide treatment of multiple myeloma. Leukemia & Lymphoma. 2002;43(2):401-406. [pmid: 11999576].
129 Neben K, Moehler T, Kraemer A, et al. Response to thalidomide in progressive multiple myeloma is not mediated by inhibition of angiogenic cytokine secretion. British Journal of Haematology. 2001;115(3):605-608. [pmid: 11736942].
130 Thompson MA, Witzig TE, Kumar S, et al. Plasma levels of tumour necrosis factor alpha and interleukin-6 predict progression-free survival following thalidomide therapy in patients with previously untreated multiple myeloma. British Journal of Haematology. 2003;123(2):305-308. [pmid: 14531913].
131 Neben K, Mytilineos J, Moehler TM, et al. Polymorphisms of the tumor necrosis factor-alpha gene promoter predict for outcome after thalidomide therapy in relapsed and refractory multiple myeloma. Blood. 2002;100(6):2263-2265. [pmid: 12200397].
132 Jaksic WJ, Trudel S, Chang H, et al. t(4;14) Positive multiple myeloma is chemosensitive to dexamethasone and/or thalidomide but not alkylating agents: rapid relapse and not primary drug resistance explains poor outcomes. Blood. 2004;104(11). Abstract #2417.
133 Shaughnessy J Jr, Tian E, Sawyer J, et al. Prognostic impact of cytogenetic and interphase fluorescence in situ hybridization-defined chromosome 13 deletion in multiple myeloma: early results of total therapy II. British Journal of Haematology. 2003;120(1):44-52. [pmid: 12492575].
134 Neben K, Moehler T, Benner A, et al. Dose-dependent effect of thalidomide on overall survival in relapsed multiple myeloma. Clinical Cancer Research. 2002;8(11):3377-3382. [pmid: 12429624].
135 Tosi P, Zamagni E, Cellini C, et al. Thalidomide alone or in combination with dexamethasone in patients with advanced, relapsed or refractory multiple myeloma and renal failure. European Journal of Haematology. 2004;73(2):98-103. [pmid: 15245508].
136 Attal M, Harousseau JL, Facon T, et al. Single versus double autologous stem-cell transplantation for multiple myeloma.[see comment][erratum appears in N Engl J Med. 2004 Jun17;350(2)2628]. New England Journal of Medicine. Dec. 25. 2003;349(26):2495-2502. [pmid: 14695409].
137 Harousseau JL. Management of multiple myeloma. [Review]. Reviews in Clinical & Experimental Hematology. 2002;6(3):253-275. [pmid: 12616698].
138 Hideshima T, Chauhan D, Shima Y, et al. Thalidomide and its analogs overcome drug resistance of human multiple myeloma cells to conventional therapy. Blood. 2000;96(9):2000.
139 Cavo M, Zamagni E, Tosi P, et al. Superiority of first-line thalidomide-dexamethasone over vincristine-doxorubicin-dexamethasone in preparation for autologous stem cell transplantation for multiple myeloma. Blood. 2004;104(11). Abstract#1489.
140 Cavo M, Zamagni E, Tosi P, et al. Superiority of thalidomide and dexamethasone over vincristine-doxorubicindexamethasone (VAD) as primary therapy in preparation for autologous transplantation for multiple myeloma. Blood. 2006;106(1):35-39. [pmid: 15761019].
141 Richardson P, Anderson K. Immunomodulatory analogs of thalidomide: an emerging new therapy in myeloma. Journal of Clinical Oncology. 2004;22(16):3212-3214. [pmid: 15249587].