# References

1 Mahoney FI, Barthel DW. Functional Evaluation: The Barthel Index. Md State Med J. 1965;14:61-5. [pmid: 14258950].
2 Lin LC, Wang SC, Chen SH, et al. Efficacy of swallowing training for residents following stroke. J Adv Nurs. 2003;44(5):469-78. [pmid: 14651695].
3 Duncan PW, Jorgensen HS, Wade DT. Outcome measures in acute stroke trials: a systematic review and some recommendations to improve practice. [see comment]. [Review] [109 refs]. Stroke. 2000;31(6):1429-38. [pmid: 10835468].
4 Geyh S, Cieza A, Kollerits B, et al. Content comparison of health-related quality of life measures used in stroke based on the international classification of functioning, disability and health (ICF): a systematic review. Qual Life Res. 2007;16(5):833-51. [pmid: 17294283].
5 Roberts L, Counsell C. Assessment of clinical outcomes in acute stroke trials. Stroke. 1998;29(5):986-91. [pmid: 9596247].
6 Mudge S, Stott NS. Outcome measures to assess walking ability following stroke: a systematic review of the literature. Physiotherapy. 2007;93:189-200. [doi: 10.1016/j.physio.2006.12.010].
7 Salter K, Jutai JW, Zettler L, et al. Evidence based review of stroke rehabilitation: Outcome measures in stroke rehabilitation. http://www.ebrsr.com/modules.html.
8 Barak S, Duncan PW. Issues in selecting outcome measures to assess functional recovery after stroke. NeuroRx. 2006;3(4):505-24. [pmid: 17012065].
9 Oxman AD, Guyatt GH. Validation of an index of the quality of review articles. J Clin Epidemiol. 1991;44(11):1271-8. [pmid: 1834807].
10 Oxman AD, Guyatt GH, Singer J, et al. Agreement among reviewers of review articles. J Clin Epidemiol. 1991;44(1):91-8. [pmid: 1824710].
11 Thoma A, Veltri K, Haines T, et al. A systematic review of reviews comparing the effectiveness of endoscopic and open carpal tunnel decompression. Plast Reconstr Surg. 2004;113(4):1184-91. [pmid: 15083019].
12 French B, Thomas LH, Leathley MJ, et al. Repetitive task training for improving functional ability after stroke. Cochrane Database of Systematic Reviews. 2007;(4):CD006073. [pmid: 17943883].
13 Brady M, Furlanetto D, Hunter RV, et al. Staff-led interventions for improving oral hygiene in patients following stroke. Cochrane Database of Syst Rev. 2006;(4):CD003864. [pmid: 17054189].
14 Stroke Unit TC. Organised inpatient (stroke unit) care for stroke. [update in Cochrane Database Syst Rev. 2007;(4):CD000197; PMID: 17943737][update of Cochrane Database Syst Rev. 2000;(2):CD000197; PMID: 10796318]. [Review] [46 refs]. Cochrane Database of Systematic Reviews. 2002;(1):CD000197. [pmid: 11869570].
15 Pollock A, Baer G, Langhorne P, et al. Physiotherapy treatment approaches for the recovery of postural control and lower limb function following stroke: a systematic review. [Review] [56 refs] 87. Clin Rehabil. 2007;21(5):395-410. [pmid: 17613560].
16 Braun SM, Beurskens AJ, Borm PJ, et al. The effects of mental practice in stroke rehabilitation: a systematic review. [Review] [60 refs]. Arch Phys Med Rehabil. 2006;87(6):842-52. [pmid: 16731221].
17 Golomb BA, Vickrey BG, Hays RD. A review of health-related quality-of-life measures in stroke. Pharmacoeconomics. 2001;19(2):155-85. [pmid: 11284381].
18 Gebski V, Marschner I, Keech AC. Specifying objectives and outcomes for clinical trials. Med J Aust. 2002;176(10):491-2. [pmid: 12065014].
19 Altman DG. Statistics and ethics in medical research: III. How large a sample?. BMJ. 1980;281:1336-8. [pmid: 7437789].
20 Geyh S, Cieza A, Schouten J, et al. ICF Core Sets for stroke. J Rehabil Med. 2004;(44 Suppl):135-41. [pmid: 15370761].
21 WHO. Stroke 1989-Recommendations on stroke prevention, diagnosis, and therapy. Report of the WHO task force on Stroke and Other Cerebrovascular Disorders. Stroke. 1989;20(10):1407-31. [pmid: 2799873].
22 National Heart, Lung and Blood Institute NHLBI. Incidence and Prevalence: 2006 Chart Book on Cardiovascular and Lung Diseases. National Heart, Lung and Blood Institute (NHLBI). http://www.nhlbi.nih.gov/resources/docs/06a_ip_chtbk.pdf.
23 Rosamond W, Flegal K, Furie K, et al. Heart Disease and Stroke Statistics 2008 Update. A Report From the American Heart Association Statistics Committee and Stroke Statistics Subcommittee. Circulation. 2008;117(4):e25-e146. [pmid: 18086926].
24 Anderson CS, Linto J, Stewart-Wynne EG. A population-based assessment of the impact and burden of caregiving for long-term stroke survivors. Stroke. 1995;26:843-9. [pmid: 7740578].
25 Centers for Medicare and Medicaid Services. Health Care Financing Review: Medicare and Medicaid Statistical Supplement. 2006 Statistical Supplement. Baltimore. Centers for Medicare and Medicaid Services. 2006.
26 Taylor TN, Davis PH, Torner JC, et al. Lifetime cost of stroke in the United States. Stroke. 1996;27(9):1459-66. [pmid: 8784113].
27 Goldstein LB, Adams R, Alberts MJ, et al. Primary Prevention of Ischemic Stroke: A Guideline From the American Heart Association/American Stroke Association Stroke Council. Stroke. 2006;37:1583-633. [pmid: 16675728].
28 O’Sullivan SB, Schmitz TJ. Physical Rehabilitation: Assessment and Treatment. 4th ed. Philadelphia. F. A. Davis Co. 2001.
29 Committee on Assessing Rehabilitation Science and Engineering IoM Enabling America. Assessing the Role of Rehabilitation Science and Engineering. Washington, D.C. National Academy Press. 1997. http://www.nap.edu/catalog/5799.html.
30 World Health Organization. International Classification of Functioning, Disability and Health: ICF. Geneva. World Health Organization. 2001.
31 Finger ME, Cieza A, Stoll J, et al. Identification of intervention categories for physical therapy, based on the international classification of functioning, disability and health: a Delphi exercise. Phys Ther. 2006;86(9):1203-20. [pmid: 16959669].
32 Steiner WA, Ryser L, Huber E, et al. Use of the ICF model as a clinical problem-solving tool in physical therapy and rehabilitation medicine. Phys Ther. 2002;82(11):1098-107. [pmid: 12405874].
33 Schepers VP, Ketelaar M, van de Port I, et al. Comparing contents of functional outcome measures in stroke rehabilitation using the International Classification of Functioning, Disability and Health. Disabil Rehabil. 2007;29(3):221-30. [pmid: 17364773].
34 Sackett DL, Rosenberg WM, Gray JA, et al. Evidence based medicine: what it is and what it isn’t. BMJ. 1996;312(7023):71-2. [pmid: 8555924].
35 Guyatt GH, Rennie D. User’s Guide to the Medical Literature: A Manual for Evidence-Based Clinical Practice. Chicago. American Medical Association Press. 2002;4.
36 Rothman KJ, Greenland S. Modern Epidemiology. 2nd ed. Philadelphia. Lippincott-Raven. 1998.
37 Silman AJ, Macfarlane GJ. Epidemiological Studies: A Practical Guide. 2nd ed. Cambridge. Cambridge University Press. 2002.
38 Concato J, Shah N, Horwitz RI. Randomized, controlled trials, observational studies, and the hierarchy of research designs. N Engl J Med. 2000;342(25):1887-92. [pmid: 10861325].
39 Horn SD, Gassaway J. Practice-based evidence study design for comparative effectiveness research. Med Care. 2007;45(10 Supl 2):S50-S57. [pmid: 17909384].
40 Benson K, Hartz AJ. A comparison of observational studies and randomized, controlled trials. N Engl J Med. 2000;342(25):1878-86. [pmid: 10861324].
41 Horn SD, DeJong G, Ryser DK, et al. Another look at observational studies in rehabilitation research: going beyond the holy grail of the randomized controlled trial. Arch Phys Med Rehabil. 2005;86(12 Suppl 2):S8-S15. [pmid: 16373136].
42 McMillan JH. Educational Research: Fundamentals for the Consumer. Boston. Allyn and Bacon. 2004;4:227-228.
43 Fulk GD. Locomotor training with body weight support after stroke: the effect of different training parameters. J Neurol Phys Ther. 2004;28(1):20-8.
44 Sheskin D. Handbook of Parametric and Nonparametric Statistical Procedures. 3rd ed. Baco Raton, FL. CRC Press. 2004.
45 Bates B, Choi JY, Duncan PW, et al. Veterans Affairs/Department of Defense Clinical Practice Guideline for the Management of Adult Stroke Rehabilitation Care: executive summary. Stroke. 2005;36(9):2049-56. [pmid: 16120847].
46 New Zealand Guidelines Group. Life After Stroke: New Zealand Guideline for Management of Stroke. Best Practice Evidence-based Guideline. Wellington, NZ. Stroke Foundation New Zealand Inc. 2003.
47 Scottish Intercollegiate Guidelines Network. Management of Patients with Stroke: Rehabilitation, Prevention and Management of Complications, and Discharge Planning. A National Clinical Guideline. Edinburgh. Scottish Intercollegiate Guidelines Network. 2002;64. http://www.sign.ac.uk.
48 Intercollegiate Stroke Working Party. National Clinical Guidelines for Stroke. 2nd ed. London. Royal College of Physicians of London. 2004.
49 Intercollegiate Stroke Working Party. Physiotherapy Concise Guide for Stroke. London. Royal College of Physicians of London. 2006.
50 VA Employee Education System. VA/DoD Clinical Practice Guidelines for the Management of Stroke Rehabilitation:Guideline Summary. Washington, DC. Department of Veterans Affairs. 2002.
51 Gordon NF, Gulanick M, Costa F, et al. Physical activity and exercise recommendations for stroke survivors: an American Heart Association scientific statement from the Council on Clinical Cardiology, Subcommittee on Exercise, Cardiac Rehabilitation, and Prevention; the Council on Cardiovascular Nursing; the Council on Nutrition, Physical Activity, and Metabolism; and the Stroke Council. Circulation. 2004;109(16):2031-41. [pmid: 15117863].
52 Brosseau L, Wells GA, Finestone HM, et al. Clinical practice guidelines for balance training. Top Stroke Rehabil. 2006;13(2):41-5.
53 Wandel A, Jorgensen HS, Nakayama H, et al. Prediction of walking function in stroke patients with initial lower extremity paralysis: the Copenhagen Stroke Study. Arch Phys Med Rehabil. 2000;81(6):736-8. [pmid: 10857515].
54 Folstein MF, Folstein SE, McHugh PR. “Mini-mental state”. A practical method for grading the cognitive state of patients for the clinician. J Psychiatr Res. 1975;12(3):189-98. [pmid: 1202204].
55 Streiner DL, Norman GR. Health Measurement Scales: A Practical Guide to Their Development and Use. 3rd ed. Oxford. Oxford University Press. 2003.
56 Schwartz AL, Meek PM, Nail LM, et al. Measurement of fatigue. Determining minimally important clinical differences. J Clin Epidemiol. 2002;55(3):239-44. [pmid: 11864794].
57 Nilsdotter AK, Lohmander LS, Klassbo M, et al. Hip disability and osteoarthritis outcome score (HOOS)--validity and responsiveness in total hip replacement. BMC Musculoskelet Disord. 2003;4. [pmid: 12777182].
58 Cramer SC, Koroshetz WJ, Finklestein SP. The case for modality-specific outcome measures in clinical trials of stroke recovery-promoting agents. Stroke. 2007;38(4):1393-5. [pmid: 17332455].
59 Salter KL, Teasell RW, Foley NC, et al. Outcome assessment in randomized controlled trials of stroke rehabilitation. Am J Phys Med Rehabil. 2007;86(12):1007-12. [pmid: 17912137].
60 Marigold DS, Eng JJ, Dawson AS, et al. Exercise leads to faster postural reflexes, improved balance and mobility, and fewer falls in older persons with chronic stroke. J Am Geriatr Soc. 2005;53(3):416-23. [pmid: 15743283].
61 Berg K, Wood-Dauphinee S, Williams JI. The Balance Scale: reliability assessment with elderly residents and patients with an acute stroke. Scand J Rehabil Med. 1995;27(1):27-36. [pmid: 7792547].
62 Berg KO, Wood-Dauphinee SL, Williams JI, et al. Measuring balance in the elderly: validation of an instrument. Can J Public Health. 1992;83(Suppl 2):S7-11. [pmid: 1468055].
63 Roerdink M, Lamoth CJC, Kwakkel G, et al. Gait coordination after stroke: benefits of acoustically paced treadmill walking. Phys Ther. 2007;87(8):1009-22. [pmid: 17553922].
64 Park J, White AR, James MA, et al. Acupuncture for subacute stroke rehabilitation: a sham-controlled, subject- and assessor-blind, randomized trial. Arch Intern Med. 2005;165(17):2026-31. [pmid: 16186474].
65 Dorman PJ, Waddell F, Slattery J, et al. Is the EuroQol a valid measure of health-related quality of life after stroke?. Stroke. 1997;28(10):1876-82. [pmid: 9341688].
66 Dorman PJ, Slattery J, Farrell B, et al. A randomised comparison of the EuroQol and Short Form-36 after stroke. United Kingdom collaborators in the International Stroke Trial. BMJ. 1997;315(7106):461. [pmid: 9284664].
67 Dorman P, Slattery J, Farrell B, et al. Qualitative comparison of the reliability of health status assessments with the EuroQol and SF-36 questionnaires after stroke. United Kingdom Collaborators in the International Stroke Trial. Stroke. 1998;29(1):63-8. [pmid: 9445330].
68 Hafsteinsdottir TB, Algra A, Kappelle LJ, et al. Neurodevelopmental treatment after stroke: a comparative study. J Neurol Neurosurg Psychiatry. 2005;76(6):788-92. [pmid: 15897499].
69 van Straten A, de Haan RJ, Limburg M, et al. A stroke-adapted 30-item version of the Sickness Impact Profile to assess quality of life (SA-SIP30). Stroke. 1997;28(11):2155-61. [pmid: 9368557].
70 Ahlsio B, Britton M, Murray V, et al. Disablement and quality of life after stroke. Stroke. 1984;15(5):886-90. [pmid: 6236588].
71 Langhammer B, Lindmark B, Stanghelle JK. Stroke patients and long-term training: is it worthwhile? A randomized comparison of two different training strategies after rehabilitation. Clin Rehabil. 2007;21(6):495-510. [pmid: 17613581].
72 Shah S. In praise of the biometric and psychometric qualities of the Barthel Index. Physiotherapy. 1994;80(11):761-71.
73 Gilmore PE, Spaulding SJ. Motor learning and the use of videotape feedback after stroke. Top Stroke Rehabil. 2007;14(5):28-36. [pmid: 17901013].
74 Klein RM, Bell B. Self-care skills: behavioral measurement with Klein-Bell ADL scale. Arch Phys Med Rehabil. 1982;63(7):335-8. [pmid: 7092535].
75 Westerberg H, Jacobaeus H, Hirvikoski T, et al. Computerized working memory training after stroke -- A pilot study. Brain Injury. 2007;21(1):21-9. [pmid: 17364516].
76 Cherney LR, Halper AS, Papachronis D. Two approaches to treating unilateral neglect after right hemisphere stroke: a preliminary investigation. Top Stroke Rehabil. 2003;9(4):22-33. [pmid: 14523697].
77 Trenerry MR, Crosson B, DeBoe J, et al. Stroop Neuropsychological Screening Test. Odessa, FL. Psychological Assessment Resources, Inc. 1989.
78 Nys GM, van Zandvoort MJ, de Kort PL, et al. Restrictions of the Mini-Mental State Examination in acute stroke. Arch Clin Neuropsychol. 2005;20(5):623-9. [pmid: 15939186].
79 Thorsen A, Widen HL, Pedro-Cuesta J, et al. A randomized controlled trial of early supported discharge and continued rehabilitation at home after stroke: five-year follow-up of patient outcome. Stroke. 2005;36(2):297-302. [pmid: 15618441].
80 Reinvang I, Engvik H. Håndbok: Norsk Grunntest for Afasi. Oslo, Norway. Universitetsforlaget. 1980.
81 Rochon E, Laird L, Bose A, et al. Mapping therapy for sentence production impairments in nonfluent aphasia. Neuropsychol Rehabil. 2005;15(1):1-36. [pmid: 16353851].
82 Caplan D, Hanna JE. Sentence production by aphasic patients in a constrained task. Brain Lang. 1998;63(2):184-218. [pmid: 9654431].
83 Goulding R, Bakheit AM. Evaluation of the benefits of monitoring fluid thickness in the dietary management of dysphagic stroke patients. Clin Rehabil. 2000;14(2):119-24. [pmid: 10763787].
84 Huang JY, Zhang DY, Yao Y, et al. Training in swallowing prevents aspiration pneumonia in stroke patients with dysphagia. J Int Med Res. 2006;34(3):303-6. [pmid: 16866025].
85 Discharge Trialists. Services for reducing duration of hospital care for acute stroke patients. Cochrane Database Syst Rev. 2005;(4):CD000443. [pmid: 15846604].
86 Larsen T, Olsen TS, Sorensen J. Early home-supported discharge of stroke patients: a health technology assessment. [Review] [28 refs]. Int J Technol Assess Health Care. 2006;22(3):313-20. [pmid: 16984059].
87 Lynton H, Kligler B, Shiflett S. Yoga in stroke rehabilitation: a systematic review and results of a pilot study. [Review] [20 refs]. Top Stroke Rehabil. 2007;14(4):1-8. [pmid: 17698453].
88 Dumoulin C, Korner-Bitensky N, Tannenbaum C. Urinary incontinence after stroke: does rehabilitation make a difference? A systematic review of the effectiveness of behavioral therapy. [Review] [52 refs]. Top Stroke Rehabil. 2005;12(3):66-76. [pmid: 16110429].
89 Urton ML, Kohia M, Davis J, et al. Systematic literature review of treatment interventions for upper extremity hemiparesis following stroke. [Review] [20 refs]. Occup Ther Int. 2007;14(1):11-27. [pmid: 17623376].
90 West C, Hesketh A, Vail A, et al. Interventions for apraxia of speech following stroke. Cochrane Database Syst Rev. 2005;(4):CD004298. [pmid: 16235357].
91 Ada L, Dorsch S, Canning CG. Strengthening interventions increase strength and improve activity after stroke: a systematic review. [Review] [60 refs]. Aust J Physiother. 2006;52(4):241-8. [pmid: 17132118].
92 Hakkennes S, Keating JL. Constraint-induced movement therapy following stroke: a systematic review of randomised controlled trials. [Review] [45 refs]. Aust J Physiother. 2005;51(4):221-31. [pmid: 16321129].
93 Henderson A, Korner-Bitensky N, Levin M. Virtual reality in stroke rehabilitation: a systematic review of its effectiveness for upper limb motor recovery. [Review] [48 refs]. Top Stroke Rehabil. 2007;14(2):52-61. [pmid: 17517575].
94 Pang MY, Eng JJ, Dawson AS, et al. The use of aerobic exercise training in improving aerobic capacity in individuals with stroke: a meta-analysis. [Review] [84 refs]. Clin Rehabil. 2006;20(2):97-111. [pmid: 16541930].
95 van Peppen RP, Kortsmit M, Lindeman E, et al. Effects of visual feedback therapy on postural control in bilateral standing after stroke: a systematic review. [Review] [13 refs]. J Rehabil Med. 2006;38(1):3-9. [pmid: 16548079].
96 van Dijk H, Jannink MJ, Hermens HJ. Effect of augmented feedback on motor function of the affected upper extremity in rehabilitation patients: a systematic review of randomized controlled trials. [Review] [47 refs]. J Rehabil Med. 2005;37(4):202-11. [pmid: 16024475].
97 Seenan P, Long M, Langhorne P. Stroke units in their natural habitat: systematic review of observational studies. [Review] [29 refs]. Stroke. 2007;38(6):1886-92. [pmid: 17463308].
98 Pomeroy VM, King L, Pollock A, et al. Electrostimulation for promoting recovery of movement or functional ability after stroke. Cochrane Database Syst Rev. 2006;(2):CD003241. [pmid: 16625574].
99 Ada L, Foongchomcheay, et al. Supportive devices for preventing and treating subluxation of the shoulder after stroke. [Systematic Review]. Cochrane Database of Systematic Reviews. 2007;(4). 2005;(4).
100 Bennett MH, Wasiak J, Schnabel A, et al. Hyperbaric oxygen therapy for acute ischaemic stroke. Cochrane Database of Syst Rev. 2005;(3):CD004954. [pmid: 16034959].
101 Bowen A, Lincoln NB. Cognitive rehabilitation for spatial neglect following stroke. [update of Cochrane Database Syst Rev. 2002;(2):CD003586; PMID: 12076489]. [Review] [61 refs]. Cochrane Database Syst Rev. 2007;119(2):CD003586. [pmid: 17443528].
102 Legg LA, Drummond AE, Langhorne P. Occupational therapy for patients with problems in activities of daily living after stroke. Cochrane Database Syst Rev. 2006;(4):CD003585. [pmid: 17054178].
103 Mehrholz J, Werner C, Kugler J, et al. Electromechanical-assisted training for walking after stroke. Cochrane Database Syst Rev. 2007;(4):CD006185. [pmid: 17943893].
104 Moseley AM, Stark A, Cameron ID, et al. Treadmill training and body weight support for walking after stroke. [update of Cochrane Database Syst Rev. 2003;(3):CD002840; PMID: 12917932]. [Review] [96 refs]. Cochrane Database Syst Rev. 2005;(4):CD002840. [pmid: 16235304].
105 Nair RD, Lincoln NB. Cognitive rehabilitation for memory deficits following stroke. Cochrane Database Syst Rev. 2007;(4):CD002293. [pmid: 17636703].
106 Thomas LH, Barrett J, Cross S, et al. Prevention and treatment of urinary incontinence after stroke in adults. [Review] [37 refs]. Cochrane Database Syst Rev. 2008;(3):CD004462. [pmid: 18254050].
107 Woodford H, Price C. EMG biofeedback for the recovery of motor function after stroke. Cochrane Database Syst Rev. 2007;(2):CD004585. [pmid: 17443550].
108 Wu HM, Tang JL, Lin XP, et al. Acupuncture for stroke rehabilitation. Cochrane Database Syst Rev. 2006;(3):CD0044131. [pmid: 16856031].
109 Zhang SH, Liu M, Asplund K, et al. Acupuncture for acute stroke. Cochrane Database Syst Rev. 2005;(2):CD003317. [pmid: 15846657].
110 Bjorklund A, Fecht A. The effectiveness of constraint-induced therapy as a stroke intervention: a meta-analysis. Occupl Ther Health Care. 2006;20(2):31-49.
111 Bonaiuti D, Rebasti L, Sioli P. The constraint induced movement therapy: a systematic review of randomised controlled trials on the adult stroke patients. [Review] [33 refs]. Eur Medicophys. 2007;43(2):139-46. [pmid: 17525700].
112 Carson S, McDonagh M, Russman B, et al. Hyperbaric oxygen therapy for stroke: a systematic review of the evidence. [Review] [36 refs]. Clinical Rehabilitation. 2005;19(8):819-33. [pmid: 16323381].
113 de Kroon JR, Ijzerman MJ, Chae J, et al. Relation between stimulation characteristics and clinical outcome in studies using electrical stimulation to improve motor control of the upper extremity in stroke. [Review] [45 refs]. J Rehabil Med. 2005;37(2):65-74. [pmid: 15788340].
114 Prange GB, Jannink MJ, Groothuis-Oudshoorn CG, et al. Systematic review of the effect of robot-aided therapy on recovery of the hemiparetic arm after stroke. [Review] [67 refs]. J Rehabil Res Dev. 2006;43(2):171-84. [pmid: 16847784].
115 Riggs RV, Andrews K, Roberts P, et al. Visual deficit interventions in adult stroke and brain injury: a systematic review. [Review] [35 refs]. Am J Physl Med Rehabil. 2007;86(10):853-60. [pmid: 17885320].
116 Robbins SM, Houghton PE, Woodbury MG, et al. The therapeutic effect of functional and transcutaneous electric stimulation on improving gait speed in stroke patients: a meta-analysis. Arch Phys Med Rehabil. 2006;87(6):853-9. [pmid: 16731222].
117 Stewart KC, Cauraugh JH, Summers JJ. Bilateral movement training and stroke rehabilitation: a systematic review and meta-analysis. [Review] [45 refs]. J Neurol Sci. 2006;244(1–2):89-95. [pmid: 16476449].
118 Delgado-Rodriguez M, Llorca J. Bias. J Epidemiol Community Health. 2004;58(8):635-41. [pmid: 15252064].
119 Boutron I, Moher D, Altman D, et al. Methods and processes of the CONSORT group: Example of an extension for trials assessing nonpharmacologic treatments. Ann Intern Med. 2008;148(4):W60-W66. [pmid: 18283201].
120 Boutron I, Moher D, Altman D, et al. Extending the CONSORT statement to randomized trials of nonpharmacologic treatment: explanation and elaboration. Ann Intern Med. 2008;148(4):295-309. [pmid: 18283207].
121 Vandenbroucke JP, von Elm E, Altman D, et al. Strengthening the reporting of observational studies in epidemiology (STROBE): Explanation and elaboration. Ann Intern Med. 2007;147(8):W163-W194. [pmid: 17938389].
122 von Elm E, Altman DG, Egger M, et al. The strengthening the reporting of observational studies in epidemiology (STROBE) statement: Guidelines for reporting observational studies. Ann Intern Med. 2007;147(8):573-7. [pmid: 17938396].
123 Whyte J. A grand unified theory of rehabilitation (we wish!). The 57th John Stanley Coulter memorial lecture. Arch Phys Med Rehabil. 2008;89:203-9. [pmid: 18226642].
124 Kreisel SH, Hennerici MG, Bazner H. Pathophysiology of stroke rehabilitation: The natural course of clinical recovery, use-dependent plasticity and rehabilitative outcome. Cerebrovasc Dis. 2007;23:243-55. [pmid: 17192704].
125 Askim T, Morkved S, Indredavik B. Does an extended stroke unit service with early supported discharge have any effect on balance or walking speed?. J Rehabil Med. 2006;38(6):368-74. [pmid: 17067970].
126 Bayouk J, Boucher JP, Leroux A. Balance training following stroke: effects of task-oriented exercises with and without altered sensory input. Int J Rehabil Res. 2006;29(1):51-9. [pmid: 16432390].
127 Bayram S, Sivrioglu K, Karli N, et al. Low-dose botulinum toxin with short-term electrical stimulation in poststroke spastic drop foot: a preliminary study. Am J Phys Med Rehabil. 2006;85(1):75-81. [pmid: 16357552].
128 Chen S, Chen Y, Chen C, et al. Effects of surface electrical stimulation on the muscle-tendon junction of spastic gastrocnemius in stroke patients. Disabil Rehabil. 2005;27(3):105-10. [pmid: 15823991].
129 English CK, Hillier SL, Stiller KR, et al. Circuit class therapy versus individual physiotherapy sessions during inpatient stroke rehabilitation: a controlled trial. [erratum appears in Arch Phys Med Rehabil. 2007 Oct;88(10):1364]. Arch Phys Med Rehabil. 2007;88(8):955-63. [pmid: 17678655].
130 Macko RF, Ivey FM, Forrester LW, et al. Treadmill exercise rehabilitation improves ambulatory function and cardiovascular fitness in patients with chronic stroke: a randomized, controlled trial. Stroke. 2005;36(10):2206-11. [pmid: 16151035].
131 Mayr A, Kofler M, Quirbach E, et al. Prospective, blinded, randomized crossover study of gait rehabilitation in stroke patients using the Lokomat gait orthosis. Neurorehabil Neural Repair. 2007;21(4):307-14. [pmid: 17476001].
132 Pang MY, Eng JJ, Dawson AS, et al. A community-based fitness and mobility exercise program for older adults with chronic stroke: a randomized, controlled trial. J Am Geriatr Soc. 2005;53(10):1667-74. [pmid: 16181164].
133 Peurala SH, Tarkka IM, Pitkanen K, et al. The effectiveness of body weight-supported gait training and floor walking in patients with chronic stroke. Arch Phys Med Rehabil. 2005;86(8):1557-64. [pmid: 16084808].
134 Peurala SH, Titianova EB, Mateev P, et al. Gait characteristics after gait-oriented rehabilitation in chronic stroke. Restor Neurol Neurosci. 2005;23(2):57-65. [pmid: 15990412].
135 Sutbeyaz S, Yavuzer G, Sezer N, et al. Mirror therapy enhances lower-extremity motor recovery and motor functioning after stroke: a randomized controlled trial. Arch Physl Med Rehabil. 2007;88(5):555-9. [pmid: 17466722].
136 Sze FK, Wong E, Yi X, et al. Does acupuncture have additional value to standard poststroke motor rehabilitation?. Stroke. 2002;33(1):186-94. [pmid: 11779909].
137 Thaut MH, Leins AK, Rice RR, et al. Rhythmic auditory stimulation improves gait more than NDT/Bobath training in near-ambulatory patients early poststroke: a single-blind, randomized trial. Neurorehabil Neural Repair. 2007;21(5):455-9. [pmid: 17426347].
138 Tong RK, Ng MF, Li LS. Effectiveness of gait training using an electromechanical gait trainer, with and without functional electric stimulation, in subacute stroke: a randomized controlled trial. Arch Phys Med Rehabil. 2006;87(10):1298-304. [pmid: 17023237].
139 Yan T, Hui-Chan CW, Li LS. Functional electrical stimulation improves motor recovery of the lower extremity and walking ability of subjects with first acute stroke: a randomized placebo-controlled trial. Stroke. 2005;36(1):80-5. [pmid: 15569875].
140 Yang YR, Wang RY, Chen YC, et al. Dual-task exercise improves walking ability in chronic stroke: a randomized controlled trial. Arch Phys Med Rehabil. 2007;88(10):1236-40. [pmid: 17908563].
141 Yavuzer G, Geler-Kulcu D, Sonel-Tur B, et al. Neuromuscular electric stimulation effect on lower-extremity motor recovery and gait kinematics of patients with stroke: a randomized controlled trial. Arch Physl Med Rehabil. 2006;87(4):536-40. [pmid: 16571394].
142 Yavuzer G, Eser F, Karakus D, et al. The effects of balance training on gait late after stroke: a randomized controlled trial. Clin Rehabil. 2006;20(11):960-9. [pmid: 17065539].
143 Askim T, Rohweder G, Lydersen S, et al. Evaluation of an extended stroke unit service with early supported discharge for patients living in a rural community. A randomized controlled trial. Clin Rehabil. 2004;18(3):238-48. [pmid: 15137554].
144 Barreca S, Sigouin CS, Lambert C, et al. Effects of extra training on the ability of stroke survivors to perform an independent sit-to-stand: a randomized controlled trial. J Geriatr Phys Ther. 2004;27(2):59-64.
145 Chae J, Yu DT, Walker ME, et al. Intramuscular electrical stimulation for hemiplegic shoulder pain: a 12-month follow-up of a multiple-center, randomized clinical trial. Am J Phys Med Rehabil. 2005;84(11):832-42. [pmid: 16244520].
146 Childers MK, Brashear A, Jozefczyk P, et al. Dose-dependent response to intramuscular botulinum toxin type A for upper-limb spasticity in patients after a stroke. Arch Phys Med Rehabil. 2004;85(7):1063-9. [pmid: 15241751].
147 Fjaertoft H, Indredavik B, Johnsen R, et al. Acute stroke unit care combined with early supported discharge. Long-term effects on quality of life. A randomized controlled trial. Clin Rehabil. 2004;18(5):580-6. [pmid: 15293492].
148 The Glasgow Augmented Physiotherapy Study (GAPS) group. Can augmented physiotherapy input enhance recovery of mobility after stroke? A randomized controlled trial. Clinl Rehabil. 2004;18(5):529-37. [pmid: 15293487].
149 Hafsteinsdottir TB, Algra A, Kappelle LJ, et al. Neurodevelopmental treatment after stroke: a comparative study. J Neurol Neurosurg Psychiatry. 2005;76(6):788-92. [pmid: 15897499].
150 Johnson CA, Burridge JH, Strike PW, et al. The effect of combined use of botulinum toxin type A and functional electric stimulation in the treatment of spastic drop foot after stroke: a preliminary investigation. Arch Phys Med Rehabil. 2004;85(6):902-9. [pmid: 15179643].
151 Kalra L, Evans A, Perez I, et al. A randomised controlled comparison of alternative strategies in stroke care. Health Technol Assess. 2005;9(18):iii-iiv. ix. x. 1. 79. [pmid: 15890138].
152 Kendall E, Catalano T, Kuipers P, et al. Recovery following stroke: the role of self-management education. Soc Sci Med. 2007;64(3):735-46. [pmid: 17079060].
153 Leeds L, Meara J, Hobson P. The impact of discharge to a care home on longer term stroke outcomes. Clin Rehabil. 2004;18(8):924-8. [pmid: 15609848].
154 Lincoln NB, Walker MF, Dixon A, et al. Evaluation of a multiprofessional community stroke team: a randomized controlled trial. Clin Rehabil. 2004;18(1):40-7. [pmid: 14763718].
155 McClellan R, Ada L. A six-week, resource-efficient mobility program after discharge from rehabilitation improves standing in people affected by stroke: placebo-controlled, randomised trial. Aust J Physiother. 2004;50(3):163-7. [pmid: 15482247].
156 Ryan T, Enderby P, Rigby AS. A randomized controlled trial to evaluate intensity of community-based rehabilitation provision following stroke or hip fracture in old age. Clinl Rehabil. 2006;20(2):123-31. [pmid: 16541932].
157 Studenski S, Duncan PW, Perera S, et al. Daily functioning and quality of life in a randomized controlled trial of therapeutic exercise for subacute stroke survivors. Stroke. 2005;36(8):1764-70. [pmid: 16040590].
158 Wayne PM, Krebs DE, Macklin EA, et al. Acupuncture for upper-extremity rehabilitation in chronic stroke: a randomized sham-controlled study. Arch Phys Med Rehabil. 2005;86(12):2248-55. [pmid: 16344019].
159 Boake C, Noser EA, Ro T, et al. Constraint-induced movement therapy during early stroke rehabilitation. Neurorehabil Neural Repair. 2007;21(1):14-24. [pmid: 17172550].
160 Daly JJ, Hogan N, Perepezko EM, et al. Response to upper-limb robotics and functional neuromuscular stimulation following stroke. J Rehabil Res Dev. 2005;42(6):723-36. [pmid: 16680610].
161 Ertel KA, Glymour MM, Glass TA, et al. Frailty modifies effectiveness of psychosocial intervention in recovery from stroke. Clin Rehabil. 2007;21(6):511-22. [pmid: 17613582].
162 Gladstone DJ, Danells CJ, Armesto A, et al. Physiotherapy coupled with dextroamphetamine for rehabilitation after hemiparetic stroke: a randomized, double-blind, placebo-controlled trial. Stroke. 2006;37(1):179-85. [pmid: 16322487].
163 Higgins J, Salbach NM, Wood-Dauphinee S, et al. The effect of a task-oriented intervention on arm function in people with stroke: a randomized controlled trial. Clin Rehabil. 2006;20(4):296-310. [pmid: 16719028].
164 Hsieh RL, Wang LY, Lee WC. Additional therapeutic effects of electroacupuncture in conjunction with conventional rehabilitation for patients with first-ever ischaemic stroke. J Rehabil Med. 2007;39(3):205-11. [pmid: 17468788].
165 Mead GE, Greig CA, Cunningham I, et al. Stroke: a randomized trial of exercise or relaxation. J Am Geriatr Soc. 2007;55(6):892-9. [pmid: 17537090].
166 Ng SS, Hui-Chan CW. Transcutaneous electrical nerve stimulation combined with task-related training improves lower limb functions in subjects with chronic stroke. Stroke. 2007;38(11):2953-9. [pmid: 17901383].
167 Olney SJ, Nymark J, Brouwer B, et al. A randomized controlled trial of supervised versus unsupervised exercise programs for ambulatory stroke survivors. Stroke. 2006;37(2):476-81. [pmid: 16410482].
168 Page SJ, Levine P, Leonard A. Mental practice in chronic stroke: results of a randomized, placebo-controlled trial. Stroke. 2007;38(4):1293-7. [pmid: 17332444].
169 Pohl M, Werner C, Holzgraefe M, et al. Repetitive locomotor training and physiotherapy improve walking and basic activities of daily living after stroke: a single-blind, randomized multicentre trial (DEutsche GAngtrainerStudie, DEGAS). Clin Rehabil. 2007;21(1):17-27. [pmid: 17213237].
170 Rydwik E, Eliasson S, Akner G. The effect of exercise of the affected foot in stroke patients -- a randomized controlled pilot trial. Clin Rehabil. 2006;20(8):645-55. [pmid: 16944822].
171 Sackley C, Wade DT, Mant D, et al. Cluster randomized pilot controlled trial of an occupational therapy intervention for residents with stroke in UK care homes. Stroke. 2006;37(9):2336-41. [pmid: 16888263].
172 van Nes IJ, Latour H, Schils F, et al. Long-term effects of 6-week whole-body vibration on balance recovery and activities of daily living in the postacute phase of stroke: a randomized, controlled trial. Stroke. 2006;37(9):2331-5. [pmid: 16902175].
173 Wittenberg GF, Chen R, Ishii K, et al. Constraint-induced therapy in stroke: magnetic-stimulation motor maps and cerebral activation. [corrected] [published erratum appears in Neurorehabil Neural Repair 2003 Sep;17(3):197]. Neurorehabil Neural Repair. 2003;17(1):48-57. [pmid: 12645445].
174 Wolf SL, Winstein CJ, Miller JP, et al. Effect of constraint-induced movement therapy on upper extremity function 3 to 9 months after stroke: the EXCITE randomized clinical trial. JAMA. 2006;296(17):2095-104. [pmid: 17077374].
175 Wu CY, Chen CL, Tsai WC, et al. A randomized controlled trial of modified constraint-induced movement therapy for elderly stroke survivors: changes in motor impairment, daily functioning, and quality of life. Arch Phys Med Rehabil. 2007;88(3):273-8. [pmid: 17321816].
176 Yagura H, Hatakenaka M, Miyai I. Does therapeutic facilitation add to locomotor outcome of body weight-supported treadmill training in nonambulatory patients with stroke? A randomized controlled trial. Arch Phys Med Rehabil. 2006;87(4):529-35. [pmid: 16571393].
177 Cirstea CM, Ptito A, Levin MF. Feedback and cognition in arm motor skill reacquisition after stroke. Stroke. 2006;37(5):1237-42. [pmid: 16601218].
178 Edmans JA, Webster J, Lincoln NB. A comparison of two approaches in the treatment of perceptual problems after stroke. Clinical Rehabilitation. 2000;14(3):230-43. [pmid: 10868718].
179 Frassinetti F, Angeli V, Meneghello F, et al. Long-lasting amelioration of visuospatial neglect by prism adaptation. Brain. 2002;125(Pt:3):608-23. [pmid: 11872617].
180 Harvey M, Hood B, North A, et al. The effects of visuomotor feedback training on the recovery of hemispatial neglect symptoms: assessment of a 2-week and follow-up intervention. Neuropsychologia. 2003;41(8):886-93. [pmid: 12667525].
181 Kimura M, Robinson RG, Kosier JT. Treatment of cognitive impairment after poststroke depression : a double-blind treatment trial. Stroke. 2000;31(7):1482-6. [pmid: 10884441].
182 Malouin F, Belleville S, Richards CL, et al. Working memory and mental practice outcomes after stroke. Arch Phys Med Rehabil. 2004;85(2):177-83. [pmid: 14966700].
183 McKinney M, Blake H, Treece KA, et al. Evaluation of cognitive assessment in stroke rehabilitation. Clin Rehabil. 2002;16(2):129-36. [pmid: 11926175].
184 Nys GM, van Zandvoort MJ, Algra A, et al. Cognitive and functional outcome after intravenous recombinant tissue plasminogen activator treatment in patients with a first symptomatic brain infarct. J Neurol. 2006;253(2):237-41. [pmid: 16142581].
185 Ozdemir F, Birtane M, Tabatabaei R, et al. Comparing stroke rehabilitation outcomes between acute inpatient and nonintense home settings. Arch Phys Med Rehabil. 2001;82(10):1375-9. [pmid: 11588740].
186 Purdy M. Increasing stroke patients’ success in self-medication programs using an interdisciplinary cognitive rehabilitation approach. Rehabil Nurs. 2007;32(5):210-3. [pmid: 17899992].
187 Pyoria O, Talvitie U, Nyrkko H, et al. The effect of two physiotherapy approaches on physical and cognitive functions and independent coping at home in stroke rehabilitation. A preliminary follow-up study. Disabil Rehabil. 2007;29(6):503-11. [pmid: 17364805].
188 Robertson IH, McMillan TM, MacLeod E, et al. Rehabilitation by limb activation training reduces left-side motor impairment in unilateral neglect patients: A single-blind randomised control trial. Neuropsychol Rehabil. 2002;12(5):439-54.
189 Robinson RG, Schultz SK, Castillo C, et al. Nortriptyline versus fluoxetine in the treatment of depression and in short-term recovery after stroke: a placebo-controlled, double-blind study. Am J Psychiatry. 2000;157(3):351-9. [pmid: 10698809].
190 Rorsman I, Johansson B. Can electroacupuncture or transcutaneous nerve stimulation influence cognitive and emotional outcome after stroke?. J Rehabil Med. 2006;38(1):13-9. [pmid: 16548081].
191 Tang QP, Yang QD, Wu YH, et al. Effects of problem-oriented willed-movement therapy on motor abilities for people with poststroke cognitive deficits. Phys Ther. 2005;85(10):1020-33. [pmid: 16180951].
192 Zeloni G, Farne A, Baccini M. Viewing less to see better. J Neurol Neurosurg Psychiatry. 2002;73(2):195-8. [pmid: 12122183].
193 Ashtary F, Janghorbani M, Chitsaz A, et al. A randomized, doubleblind trial of bromocriptine efficacy in nonfluent aphasia after stroke. Neurology. 2006;66(6):914-6. [pmid: 16567711].
194 Bakheit AM, Shaw S, Barrett L, et al. A prospective, randomized, parallel group, controlled study of the effect of intensity of speech and language therapy on early recovery from poststroke aphasia. Clin Rehabil. 2007;21(10):885-94. [pmid: 17981847].
195 Berthier ML, Green C, Higueras C, et al. A randomized, placebo-controlled study of donepezil in poststroke aphasia. Neurology. 2006;67(9):1687-9. [pmid: 17101908].
196 Doesborgh SJ, van de Sandt-Koenderman MW, Dippel DW, et al. Effects of semantic treatment on verbal communication and linguistic processing in aphasia after stroke: a randomized controlled trial. Stroke. 2004;35(1):141-6. [pmid: 14657447].
197 Kessler J, Thiel A, Karbe H, et al. Piracetam improves activated blood flow and facilitates rehabilitation of poststroke aphasic patients. Stroke. 2000;31(9):2112-6. [pmid: 10978039].
198 Laska AC, von Arbin M, Kahan T, et al. Long-term antidepressant treatment with moclobemide for aphasia in acute stroke patients: a randomised, double-blind, placebo-controlled study. Cerebrovasc Dis. 2005;19(2):125-32. [pmid: 15644624].
199 Pulvermuller F, Neininger B, Elbert T, et al. Constraint-induced therapy of chronic aphasia after stroke. Stroke. 2001;32(7):1621-6. [pmid: 11441210].
200 Smania N, Aglioti SM, Girardi F, et al. Rehabilitation of limb apraxia improves daily life activities in patients with stroke. Neurology. 2006;67(11):2050-2. [pmid: 17159119].
201 Walker-Batson D, Curtis S, Natarajan R, et al. A double-blind, placebo-controlled study of the use of amphetamine in the treatment of aphasia. Stroke. 2001;32(9):2093-8. [pmid: 11546902].
202 Wolfe CD, Tilling K, Rudd AG. The effectiveness of community-based rehabilitation for stroke patients who remain at home: a pilot randomized trial. Clin Rehabil. 2000;14(6):563-9. [pmid: 11128729].
203 Carnaby G, Hankey GJ, Pizzi J. Behavioural intervention for dysphagia in acute stroke: a randomised controlled trial. Lancet Neurol. 2006;5(1):31-7. [pmid: 16361020].
204 Crary MA, Carnaby GD, Groher ME, et al. Functional benefits of dysphagia therapy using adjunctive sEMG biofeedback. Dysphagia. 2004;19(3):160-4. [pmid: 15383945].
205 Dennis MS, Lewis SC, Warlow C, et al. Effect of timing and method of enteral tube feeding for dysphagic stroke patients (FOOD): a multicentre randomised controlled trial. Lancet. 2005;365(9461):764-72. [pmid: 15733717].
206 Ebihara T, Ebihara S, Maruyama M, et al. A randomized trial of olfactory stimulation using black pepper oil in older people with swallowing dysfunction. J Am Geriatr Soc. 2006;54(9):1401-6. [pmid: 16970649].
207 Freed ML, Freed L, Chatburn RL, et al. Electrical stimulation for swallowing disorders caused by stroke. Respir Care. 2001;46(5):466-74. [pmid: 11309186].
208 Hamidon BB, Abdullah SA, Zawawi MF, et al. A prospective comparison of percutaneous endoscopic gastrostomy and nasogastric tube feeding in patients with acute dysphagic stroke. Med J Malaysia. 2006;61(1):59-66. [pmid: 16708735].
209 Iizuka M, Reding M. Use of percutaneous endoscopic gastrostomy feeding tubes and functional recovery in stroke rehabilitation: a case-matched controlled study. Arch Phys Med Rehabil. 2005;86(5):1049-52. [pmid: 15895356].
210 Power ML, Fraser CH, Hobson A, et al. Evaluating oral stimulation as a treatment for dysphagia after stroke. Dysphagia. 2006;21(1):49-55. [pmid: 16544087].
211 Seki T, Iwasaki K, Arai H, et al. Acupuncture for dysphagia in poststroke patients: a videofluoroscopic study. J Am Geriatr Soc. 2005;53(6):1083-4. [pmid: 15935049].