# Acknowledgements

The authors would like to thank the following people for their invaluable assistance with literature searches, data abstraction, article retrieval and screening and editing:

Maureen Rice, Jinhui Ma, Mary Gauld, Cecile Royer, and Roxanne Cheeseman.

Thank you to the following people who helped with data abstraction:

Rachel Morris, Paula Robinson, Homa Keshavarz, Sara Kaffashian, Lynda Booker, Solina Yoo, Amanda Lo, Connie Freeborn, Liza Stathokostas, and Robert Stevens.

A final thank you to Rashmi D’Mello, Sara Shepley and Sarah Smith for their help with article retrieval and data management.