# Executive Summary

## Introduction

The Coverage and Analysis Group at the Centers for Medicare and Medicaid Services (CMS) requested this technology assessment on the methodology of studies in stroke rehabilitation therapy from The Technology Assessment Program (TAP) at the Agency for Healthcare Research and Quality (AHRQ). AHRQ assigned this report to the following Evidence-based Practice Center: McMaster University (MU-EPC) (Contract Number: HHSA 290-2007-10060-I). The assessment served as background information for a CMS Evidence Forum and the Medicare Evidence Development and Coverage Advisory Committee (MedCAC) meeting held on May 21, 2008. The primary goal of the assessment was to describe key methodological issues in studies designed to assess rehabilitation therapies administered to patients with stroke. Researchers in stroke rehabilitation may wish to use this assessment as a guide to help avoid pitfalls in the design and conduct of future studies.

### Key Question

The overarching, key research question for this technology assessment was: “What are the key methodological issues (internal validity) in comparative studies designed to assess rehabilitation therapies administered to stroke patients?” A secondary purpose of the assessment was to critically appraise the adequacy of measures used to assess outcomes in six domains of interest: ambulation, quality of life (QoL) (including caregiver burden), activities of daily living (ADLs), cognition, speech and communication, and swallowing and dysphagia. Of special importance was the need to evaluate the psychometric properties of these measures when used in comparative studies. The consultation process with AHRQ and CMS also identified 10 key attributes of studies that would be evaluated to address the overarching research question. These attributes included:

1. Study design (e.g., randomized controlled trial, observational study, etc.);
2. Randomization and blinding;
3. Patient selection criteria and characteristics;
4. Characteristics of personnel performing the intervention (including training needed);
5. Timing of the intervention relative to the stroke;
6. Frequency and duration of the intervention;
7. Length of followup in the trial and durability of benefit;
8. Prior and concurrent treatments in relation to the studied intervention;
9. Comparator used and relationship of the comparator to current best practices in stroke rehabilitation; and
10. Outcome measures used;
  a. Relation to ICF domains;
  b. Reliability, validity, and reproducibility; and
  c. MCID.

## Methods

### Literature Search Strategy

We adopted two strategies. In the first strategy (purposive sampling) the literature search was designed to identify articles that evaluated therapies in the six domains mentioned above. The objective was to identify a maximum of 20 articles per domain. In cases where fewer than 20 articles were selected into a particular domain, the time scope of the search was not broadened because few comparative studies were likely to exist in that domain. MEDLINE^®^ and CINAHL^®^ were the primary databases used in the purposive sampling strategy, with supplementation by PsycINFO^®^ in the case of the three domains with clear psychological components (i.e., cognition, communication, dysphagia). In the second strategy, a search was undertaken to identify systematic reviews on the general topic of stroke rehabilitation. MEDLINE^®^, CINAHL^®^, and the Cochrane Database of Systematic Reviews (CDSR) were the databases searched as part of the second strategy. Search scope varied, but the widest range was from January 2000 through late–January 2008.

Inclusion/exclusion criteria. For purposive sampling, included articles had to be published in English and involve human subjects. The main focus had to be stroke (or cerebrovascular accident). The study design had to contain a distinct comparison group. Included studies had to involve any type of rehabilitation therapy whose effect was evaluated using any type of outcome measure in at least one of the six domains of interest. In the case of drugs used as rehabilitation therapies, included studies had to contain a drug that was employed to treat cognitive impairment. Other types of rehabilitation drug studies were excluded.

These criteria were applied to the review of reviews, although eligible articles had to be systematic reviews of the literature. Also, reviews involving drug treatments had to evaluate medications that were used for rehabilitation, not for prevention or the treatment of post-stroke depression or emotionalism.

### Data Screening and Abstraction

Two independent reviewers applied the inclusion and exclusion criteria to the titles and abstracts of all articles retrieved in the literature search. Within each outcome domain, the first 20 matching articles from both reviewers’ lists, in order of publication date (most to least recent), advanced to data abstraction. The reviewers entered abstracted data into evidence tables. Disagreements between reviewers were resolved by consensus. Studies or reviews could be excluded at the abstraction stage if they failed to meet the inclusion/exclusion criteria.

Quality assessment. For the primary studies, we evaluated methodological characteristics and summarized them in tabular form. We also summarized two studies per outcome domain in the text: one study that exemplified good methodological quality and one study that exemplified less than high methodological quality. For the review of reviews, we developed a standardized checklist for quality focusing on four main aspects of internal validity, namely randomization allocation concealment, blinding, withdrawals, and control of baseline confounders (for cohort studies).

## Results

### Purposive Sampling

A total of 1,674 citations were retrieved in the literature search. After screening, the reviewers included and abstracted data for 99 studies. A brief summary of the key characteristics of these 99 studies follows.

Study design. The vast majority of abstracted studies (>88 percent) were Randomized Controlled Trials (RCTs). The highest percentage of RCTs was in the activities of daily living (ADL) (100 percent); the lowest percentage was in the dysphagia group (67 percent). From the viewpoint of evidence-based practice (EBP), good quality RCTs form the highest possible level of evidence for or against a therapeutic intervention.

Patient selection. All except two abstracted studies reported inclusion and exclusion criteria and at least rudimentary sample characteristics such as age and sex.

Randomization and blinding. The authors of virtually all of the abstracted RCTs reported that their subjects were randomized to treatment. Similarly, a majority of authors in all except the cognition domain reported that some type of blinding was pursued in their studies (e.g., blinding of outcome assessors).

Providers. In the abstracted studies, the majority of authors mentioned the type of health professional that was required to administer a therapy. Studies that omitted specific mention of professional status generally reported that rehabilitation interventions were delivered by a rehabilitation team, medical doctor, or one of the study researchers.

Timing of post-stroke initiation of intervention. In the abstracted studies, all of the authors in the ambulation domain reported the timing of initiation. In the other five domains, 65 percent of the authors reported the timing.

Frequency and duration of intervention. In all except the dysphagia domain, most of the studies contained reports of both the frequency and duration of the interventions. In the dysphagia studies, only half contained reports of both items.

Length of followup. In the abstracted studies, lengths of followup varied widely, although they typically fell within a band of 1 to 12 months. The authors of eight studies did not report length of followup.

Prior and concomitant treatments. Slightly more than half of the abstracted studies did not contain reports of prior or concomitant treatment, making this the least often reported key characteristic of the studies.

Standard treatment clearly described. Virtually every study reported details of the standard treatment. For example, they reported what was done to patients as part of standard rehabilitation therapy.

Outcome measurement instruments. At least 20 different outcome measurement instruments were used in each domain. Some of these instruments were well-established scales such as the Barthel Index1 and others were vaguely described tools such as a “swallowing questionnaire”.2 In the ambulation, quality of life (QoL), ADL, and cognition domains, the most frequently used instruments were reliable and valid in stroke patients. Some of these instruments were also responsive to change in stroke patients. There was very little information on the minimum clinically important difference (MCID) for any of the instruments. In the communication and dysphagia domains, there was no information on any psychometric properties for any of the instruments. It should be noted that our assessment of each instrument’s psychometric properties in stroke was based on whether the authors who used the instrument actually discussed psychometric properties in the methods sections of their study reports. Additional information on the presence or absence of psychometric properties in stroke was gleaned from information presented in the systematic review articles3–6 and two reviews of outcome measures.7,8

With respect to the above summaries, there are several important methodological points to consider when evaluating studies in stroke rehabilitation. The important methodological points are:

1. RCTs or high-quality observational studies (e.g., cohort, case control studies) are the ideal type of study design;
2. The sample characteristics of subjects should be presented in a table (stratified by treatment group);
3. Inclusion and exclusion criteria should be clearly listed in the study methods;
4. Details of randomization and blinding should be reported in the studies;
5. Authors should describe the type of professional needed to provide the therapy;
6. Authors should report the timing, frequency, and duration of the interventions in their study;
7. Authors should report the length of followup;
8. Authors should report any prior or concomitant treatments received by study subjects;
9. The comparator treatment should be clearly described; and
10. Outcome measurement instruments should only be selected if they have strong psychometric properties in stroke patients (reliability, validity, responsiveness to change).

### Review of Reviews

The initial literature search yielded a total of 949 English-language citations. After screening, a final set of 38 systematic reviews were eligible for full data extraction. We further categorized these reviews into those published within the Cochrane Database of Systematic Reviews (n = 18) and those that were not (n = 20). Those within the Cochrane systematic reviews were grouped separately, as these reflected a more standardized methodology, and internal peer review process.

Methodologic quality of the systematic reviews. The majority of systematic reviews were well conducted, with only 22 percent (n = 8) of the reviews scoring below 14 out of 18 on the Oxman and Guyatt quality assessment scale9,10 with adapted scoring.11

Methodological quality of studies within the systematic reviews. There were some methodological quality domains that were not sufficiently evaluated or reported in the studies. In particular, the potential for contamination or cointervention was not reported well in all but four Cochrane reviews12–15 and one non-Cochrane review,16 indicating poor evaluation of this criterion across all reviews. Similarly, comparing baseline characteristics of the treatment and comparator groups was not evaluated in 10 Cochrane and 11 non-Cochrane reviews, reflecting little differences between the two groups of reviews.

There were some differences between the Cochrane and non-Cochrane reviews. None of the Cochrane reviews failed to report randomization or allocation concealment. Six Cochrane reviews (35 percent) did not evaluate the potential for adverse events compared to 13 (58 percent) of the non-Cochrane reviews. With regards to blinding, many trials evaluated within the systematic reviews indicated that it was impossible to blind the therapist or patient to the treatment and therefore did not evaluate patient or provider blinding. Both Cochrane and non-Cochrane reviews did not test for the status of the data collector. However, they did assess the blinding status of the outcomes assessor (albeit the non-Cochrane reviews evaluated this less frequently).

Summary of findings. With respect to the review of reviews, there were several trends and methodological points to consider:

1. Most systematic reviews restricted studies to the intervention of interest, and by the type of stroke acuity. Few reviews restricted eligible studies to specific outcomes or to a specific provider of treatment.
2. The Cochrane reviews evaluated predominately randomized trials and the non-Cochrane reviews included all types of designs.
3. Most of the systematic reviews scored relatively high on quality criteria; those that had lower quality scores were non-Cochrane reviews and included multiple design types.
4. Most systematic reviews evaluated methodological aspects of the eligible studies with standardized checklist or criteria. The majority of reviews evaluated randomization, blinding, and withdrawals/dropouts. Fewer reviews evaluated baseline comparability, evaluation of adverse events, and co-intervention or contamination.
5. Many reviews indicated that blinding of the patient and the provider was not possible with the stroke rehabilitation intervention and as such the reviews did not evaluate eligible studies for this criterion.

### Systematic Reviews of Outcomes in Stroke Patients

Characteristics of the reviews. Three systematic reviews3,4,6 evaluating outcomes within stroke populations were identified through the literature search. Two additional systematic reviews5,17 were identified from searching the reference lists of these reviews. One of these reviews,5 published in 1998, was added because of its historical value and because this review had a broader scope in the studies it reviewed relative to the other more recent systematic reviews.

Findings. All review authors recommend the selection of outcome measures that have established psychometric properties (reliable, valid, and responsive). In addition, floor and ceiling effects (where scores are extremely high or very low making it difficult to detect changes over time), as well as practical administration issues, should be considered when selecting outcomes.4 In general, the reviews appear to suggest that no measure is able to capture the breadth of the domains that they are attempting to capture and as such the recommendation is to include other measures that capture other domains (e.g., activity level and not just impairment).5 Similarly, there is the recommendation to use more than one outcome measure in order to capture all attributes within the domain of interest (for example walking ability); however, there was some acknowledgement that consensus has not yet been achieved to define the concepts that should be captured to most accurately reflect the range of some aspects of function (such as walking).6

Only one review3 evaluated the time-points selected for evaluating final outcomes in stroke patients (e.g., 3 or 6 months post-treatment). In this review, based on 51 studies evaluating the use of drugs in acute stroke, the majority of citations evaluated patients at 3 months and none exceeded 1 year. Two reviews3,5 described the statistical methods used to evaluate rehabilitation effects; the findings of both reviews would suggest that there is a need to establish the degree of change that is considered to be clinically significant and that appropriate statistical analyses be undertaken within future studies.

Summary of findings. The systematic reviews of the outcome measures used in studies with stroke patients would indicate the following:

1. A variety of outcomes have been used to measure the same attributes of interest within studies of rehabilitation interventions in persons with stroke.
2. Currently, no single outcome measure captures all relevant dimensions of important attributes of interest to stroke patients and clinicians. This implies that measures that capture these multiple domains be included. Whether a single measure captures more than a one dimension (e.g., body function and activity and participation) or whether several measures are used to capture the dimension is less critical than ensuring that all domains are captured.
3. All dimensions of an outcome of interest should be evaluated. For example, if walking ability is of interest, then walking in all life conditions (including walking within the home, outside the home in uneven ground, and in changing weather conditions) should be evaluated.
4. Future studies evaluating rehabilitation therapies in stroke patients should select outcome measures that have established psychometric properties in stroke (reliable, valid, and responsive).
5. Consideration for selection of measures should also be given to the potential for floor and ceiling effects and practical administration issues.
6. The timing of outcome measurement should be justified, with some consideration of the natural history of stroke recovery.

## Discussion

### Methodological Issues From the Purposive Sampling

Several consistent themes emerged from the purposive sampling exercise and suggested potential areas of improvement for future studies in stroke rehabilitation. A few RCTs enrolled and randomized less than 10 subjects in total. The ability to draw any meaningful efficacy conclusions from such small studies is severely compromised by the obvious lack of power to detect effects and the high possibility of random sample error. Authors should enrol large enough samples to detect clinically significant effects, not just statistically significant effects. Authors should also be explicit in the methods with respect to their sample size calculations. Specifically, they should provide the MCID and justify their selection of such a difference. Few of the authors of the abstracted studies provided or justified a particular MCID.

Descriptions of blinded assessors and the randomization process suggest that some authors made attempts to minimize bias and confounding. However, many authors reported only rudimentary patient data, which were often limited to a few variables such as age, sex, and education. Comorbidity and concomitant treatments were often not reported. In an RCT with proper randomization, this is less of a concern because the randomization should create comparable treatment groups, thus cancelling the effect of any confounding due to comorbidity and concomitant treatment. In observational studies, though, confounding could occur if the treatment groups differ on these (or other) characteristics. Therefore, it is especially important for the authors of observational studies to present the details of all possible confounders when they report sample characteristics.

Study authors should provide a complete description of the study sample. This lends itself to establishing generalizability. Strict inclusion and exclusion criteria in many RCTs exclude persons with common comorbidities and concomitant treatments. Full disclosure of sample characteristics is required so that readers of trial reports can assess whether the subjects in an RCT are representative of a particular group of patients. If they are not representative, then the findings of the RCT may not be applicable to that particular group.

Length of followup also requires careful consideration in future studies of stroke rehabilitation therapies. Improvements to cognition and communication may take months, even years, so studies should be long enough to assess these outcomes. For ambulation, short followups are generally adequate due to the relatively rapid recovery periods for motor function and gait. Followups for QoL are less amenable to precise time specification because QoL itself involves a subjective component that may be independent of improvement in any one domain. Ideally, QoL should be measured at the same time points as the primary outcome. ADLs, like cognition, can improve over time. This would suggest medium- to long-term followup. The dysphagia studies tended to focus on interventions that would allow patients to begin adapting to swallowing problems, rather than on interventions that would correct the problems. Therefore, the dysphagia studies typically lasted for periods of weeks, which was long enough to assess whether the interventions would help patients adapt.

The authors of many studies examined a variety of different outcomes. In some studies, one outcome was specified as the primary outcome, while in others there was no named primary outcome. The use of many outcomes reflects the multifaceted nature of both the sequelae of stroke and the impact of the interventions. However, rehabilitation programs and devices are usually designed to make an impact on a narrow band of outcomes, with additional effects on other outcome areas being a ‘spin-off’ of the main impacts. Consequently, one outcome should be designated as the primary outcome. Sample size calculations should be based on the primary outcome to ensure that important inter-group differences can be detected in the study.18,19

Many of the outcome measurement instruments used in the abstracted studies were not assessed for reliability and validity in persons undergoing stroke rehabilitation. Similarly, there were few assessments for responsiveness to change and MCID in stroke. Researchers should make every attempt to employ outcome measurement instruments that have been validated in stroke patients. It is not sufficient to rely on the most popular instrument without consideration of psychometric properties because an often used, invalid instrument will produce invalid results.

### Methodological Issues From the Review of Reviews

The individual trials in stroke rehabilitation, regardless of therapy, for the most part did not have blinded patients or healthcare providers, but did have blinded outcome assessors. Adequate randomization and allocation as well as adequate accounting for all subjects continued to be a problem in many trials. Few of the systematic reviews evaluated the comparability of groups at baseline, the potential for adverse events, or problems with contamination and cointervention. In this regard, it is difficult to generalize regarding methodological problems within any of the trials being evaluated in a review. These three factors do affect internal validity and would be important to evaluate in future trials within systematic reviews.

When considering the population characteristics being evaluated in the trials, the variation in the study populations evaluated may reflect that some therapies are logically restricted to specific phases of stroke rehabilitation; however there were a fair number of interventions that were directed to all phases of the recovery continuum and the rationale for this was not always adequately presented. When considering the sample sizes within these trials, there was great variation, but in general they were not large relative to drug trials. As noted previously in the purposive sampling, adequate sample size is related to power and the ability to detect differences amongst groups; this is particularly relevant for studies selecting multiple outcome measures.

The systematic reviews evaluating the use and classification of outcomes used in the treatment of stroke patients were consistent in their recommendations. Although, the evaluation of these outcomes was not restricted to “rehabilitation” studies per se, the conclusions were applicable to this phase of intervention. Most of the reviews on outcomes used in stroke patients, noted that some outcomes frequently used in the studies had not had psychometric properties established for stroke patients. In general, there was some concern with potential difficulties with instruments that are self or interviewer administered questionnaires being applied to stroke patients (due to deficits in cognition and communication). Additionally, at least one review pointed to the timing of outcome assessment; suggesting that the rationale for the interval to measure outcomes during the recovery process was in need of greater refinement (particularly in light of the natural history of stroke recovery).

All the systematic reviews on outcome measures in stroke rehabilitation would support the use of overlap across types of measures (generic versus disease specific) and domains covered within the outcomes selected. In the former case, it was clear that no single measure would capture all the important attributes (considering the ICF framework) to evaluate within stroke patients; as such the recommendation was to include multiple outcomes to cover the breadth of functions or alternatively to develop new and more comprehensive measures. The core set of ICF functions proposed20 would be an initial, universal frame of reference to assist in selecting a minimum set of functions to be considered when selecting outcome measures for evaluating the efficacy of studies.

### Conclusion

The methodological quality of studies in stroke rehabilitation was reviewed in accordance with the components of the key question. Researchers in the field recognize the benefits of investigating interventions using the RCT design, but the reporting of randomization methods and comparability between groups was lacking in some instances. Blinding is difficult to conduct in stroke rehabilitation studies because the nature of the interventions is obvious to patients and healthcare providers alike. Many researchers in stroke recognize these limitations and try to balance the rigor of adequate blinding and the feasibility of applying the interventions.

Major methodological problems involved sample size and the psychometric properties of outcome measurement instruments. Sample size was sometimes too small to have adequate power to detect meaningful effects. Many authors failed to show sample size calculations or report an MCID. For many of the instruments used to measure outcomes, the psychometric properties in the stroke population were not tested. The road forward looks positive regarding the methodological quality of studies in stroke rehabilitation. However, despite some high quality research that conforms to the principles of EBP, there is still room for improvement, especially in the areas outlined above.

The review of reviews showed that most systematic reviews were undertaken with adequate rigour and presented the evidence for stroke rehabilitation adequately. Many of the reviews evaluated high level study designs (e.g., randomized trials); however, not all of these trials were conducted in a sufficiently rigorous manner. Most systematic reviews evaluated methodological aspects of the eligible studies with standardized checklist or criteria. The majority of reviews evaluated randomization, blinding, and withdrawals/dropouts. Fewer reviews evaluated baseline comparability, evaluation of adverse events, and cointervention or contamination. Many reviews indicated that blinding of the patient and the provider was not possible in stroke rehabilitation and as such did not evaluate eligible studies for this criterion. These findings concur with those of the purposive sampling.

Our review of reviews on outcome measures in stroke showed that a variety of outcomes have been used to measure the same attributes of interest within studies of rehabilitation interventions in persons with stroke. Currently, no single outcome measure captures all relevant dimensions of important attributes of interest to patients and clinicians. This implies that multiple measures may need to be included to capture all these important domains. Moreover, there is a need to determine the degree of comprehensiveness required when evaluating some of these outcomes of interest.

All reviews on outcome measures in stroke recommended that future studies evaluating rehabilitation therapies in stroke patients should select outcome measures that have established psychometric properties (reliable, valid, and responsive). Additional consideration should also be given to the potential for floor and ceiling effects and practical administration issues. Moreover, the timing of outcome measurement should be justified, with some consideration of the natural history of stroke recovery. These findings also concur with those of the purposive sampling.