# Discussion

The overarching aim of this technology assessment is to provide background material for a Center for Medicare and Medicaid Services (CMS) Evidence Forum and Medicare Evidence Development and Coverage Advisory Committee (MedCAC) meeting to inform policy on the evaluation of innovative training approaches in stroke rehabilitation. This technology assessment contains descriptions of key methodological issues in studies designed to assess rehabilitation therapies. The focus of the technology assessment is not on the efficacy of specific therapies, but rather on the methodological strengths and weaknesses of the studies undertaken to assess the efficacy of stroke rehabilitation therapies. To this end, we evaluated the methodological quality of both primary studies and systematic reviews.

For the primary studies, we undertook a purposive sampling of English language, comparative studies that were selected according to the outcome domains used to evaluate the therapy. This approach was conducted under the assumption that the therapy being evaluated would have limited impact on the methodological appraisal of the study in question. From our point of view, good study design should be undertaken in any stroke rehabilitation study, regardless of the type of therapy under evaluation. In choosing to delimit studies within our purposive sampling to comparative studies, we considered only randomized controlled trials (RCTs), quasi-randomized, and observational (cohort, case control, cross sectional) designs. This choice reflects studies with significant potential to reduce biases in their evaluations. The purposive sampling did not reflect the degree to which any specific rehabilitation therapy was evaluated using comparative designs versus other designs that are more prone to bias (e.g., case series).

The systematic reviews, like the primary studies within the purposive sampling, were limited to English-language reviews delimited by publication year. Once again, the assumption was that the rehabilitation therapy being evaluated did not affect the methodological issues of interest for the technology assessment. Evaluating the methodological quality of systematic reviews that included mixed study designs may have been disadvantageous (using conventional quality criteria) because many of these reviews included noncomparative studies.

There are a number of biases that can be evaluated within a primary study or systematic review. Depending on the classification system and study design, these biases can number over 200.^118^ We limited the evaluation of biases to ones consistent with internal validity (e.g., randomization rather than funding bias), provided they had a broad level of applicability (i.e., selection bias rather than healthcare access bias) and had attributes that were of specific interest to CMS. We acknowledge that there are many more specific biases that were not reported or evaluated in this technology assessment.

Finally, the extent to which we evaluated methodologic criteria within each primary study or systematic review was a function of the adequacy of reporting within each of these publication types. The dilemma always remains that researchers may have adequately undertaken the means to prevent bias, but they did not adequately report these means in the published study manuscript. No attempt on our part was made to contact authors to resolve this dilemma.

The reporting issue also applies to the assessment of the psychometric properties of outcome measurement instruments. We relied on the authors of individual studies in the purposive sample to report that the instruments used in their research were assessed for reliability, validity, and responsiveness to change in stroke populations. We also relied on the published findings of systematic reviews to assess psychometric properties. Study authors, or the authors of review articles, may not have reported on the psychometric properties of a particular instrument. Consequently, the assessment of psychometric properties in this report cannot be considered definitive. Also, it was not possible, due to the aforementioned approach, to determine whether a link existed between an instrument’s psychometric properties and its mode of administration (e.g., self-report, proxy). Ideally, primary studies on the development of each instrument should be consulted to determine the presence of psychometric properties in stroke applications.

## Ideal Reporting Standards for Comparative Studies

Recognizing the problem of poor reporting in studies, there are a number of established guidelines designed to encourage clear and transparent reporting of methods and results. The purpose of these guidelines is to permit a critical appraisal of the methods used in any study. In February 2008, the Consolidated Standards for Reporting Trials (CONSORT) amended their 22-item checklist for reporting RCTs. The amendments take into account new methodologic research and the related reporting requirements. The original reporting criteria (e.g., randomization, blinding, and withdrawals) were adapted or extended if necessary.

In the revised CONSORT guidelines, amendments were undertaken to address specific areas where more detail was required to evaluate the potential for bias in nonpharmacologic interventions such as surgery, rehabilitation, physiotherapy, or behavioral therapy.119,120 Amendments included improved descriptions of the complexity of the intervention, the training and expertise of the care provider, and difficulties related to blinding.

The CONSORT statement identifies changes in the description of the non-pharmacologic intervention, adding three new criteria and modifying the existing two. The CONSORT statement recommends that there is “precise” description of the experimental and comparator interventions such that:

1. The different components of the intervention are detailed (particularly when interventions are tailored to individuals);
2. The manner in which interventions are standardized;
3. How adherence of the care providers to the protocol was assessed or enhanced;
4. A detailed description of the of the exact manner in which the treatment and comparator interventions were implemented;
5. With regards to the caregivers (and treatment centers), the CONSORT statement recommends adequate reporting such that:
  a. The care providers or centers be described (case volume, qualification, expertise, etc.) in each group;
  b. The number of care providers or centers performing the interventions in each group and the number of patients treated by each care provider, or in each center be shown in the flow diagram; and
  c. Eligibility criteria for those performing the interventions be described.

With regards to blinding, the new recommendations concern the reporting of the masking status of persons administering cointerventions. The reporting of the blind status of the patient, the provider, and the outcomes assessor continues to be recommended. Finally, the amended CONSORT statement requires that the interpretation of study findings take into account the choice of comparator, lack of partial blinding, and unequal expertise of care providers or centers in each intervention group. Moreover, discussions about the generalizability of the study’s findings should consider the choice of the comparator and the care providers (and centers) in addition to the patients. The complete requirements for reporting on clinical trials are described elsewhere.119,120

As noted previously, in stroke rehabilitation, the customized, multifactorial approach to treatment often makes RCTs an impractical means of assessing a specific therapy.41 RCTs are more suited to situations where a unimodal therapeutic regimen (e.g., one single drug or its comparator) is given to patients. As such, we included observational studies with cohort, case control, or cross sectional designs. The Strengthening the Reporting of Observational Studies in Epidemiology (STROBE) statement makes reporting recommendations for such study designs.121,122 The STROBE statement indicates that the outcomes, exposure, predictors, confounders, and effect modifiers should be clearly defined. In the context of rehabilitation therapy, this would include the therapies administered and other concomitant treatments. Detail regarding the care providers is not specified within the STROBE reporting recommendations. However, the nature of professionally delivered stroke rehabilitation therapies suggests that such details should be reported in the case of studies designed to evaluate rehabilitation interventions. The STROBE does recommend an explanation of sample size. Such an explanation would be of benefit in clinical trials as well.

Both the extended CONSORT and STROBE statements provide clear recommendations for reporting in studies that are designed to evaluate new and innovative stroke rehabilitation therapies. Adherence to these reporting recommendations would lead to a clear and transparent understanding of the research undertaken and allow for adequate critical appraisal of methods.

Finally, it should be recognized that the potential for bias in studies continues to exist even if there is adherence to the reporting standards of CONSORT or STROBE. A comparator therapy, for example, can be well described, but the content and dose of the intervention be biased such that the treatment group may appear to have a substantive relative effect. Some justification for the types of comparators, even if well described, would be required.

## Study Design Challenges in Stroke Rehabilitation Therapy

There are many challenges inherent in designing studies to evaluate stroke rehabilitation therapies. One such challenge is deciding on a viable comparator. The issue is that the choice of the comparator could influence the observed treatment effect. Choices for a comparator group include a placebo, usual care, another active treatment, or no treatment (e.g., a wait list). If the choice is ‘no treatment’, the intervention has a greater likelihood to be shown to be effective. In interpreting this type of study, the question is whether ‘no treatment’ reflects reality in the clinical world. In many rehabilitation situations, clients are receiving some kind of treatment. To evaluate a new intervention, there should be a comparator reflecting usual care or another active treatment. In these trials, the details of both the intervention and comparator are essential to assess the internal and external validity of the study and ultimately decide whether the intervention should be implemented for the targeted client group.

The details about the experimental and control interventions should include information on the intended intervention and the actual intervention that was administered in both groups. The descriptions about the intended experimental and comparator (control) interventions need to include the theoretical basis for choosing the interventions, the characteristics of the care providers, and the timing, intensity, and planned modifications in relation to client characteristics. The theoretical rationale is particularly important for the experimental intervention. Similar to pharmacological research, where the mechanism of action of the drug is the basis for the research, the theoretical basis in rehabilitation research is essential for designing and understanding the principles of the intervention.123 In particular, when multimodal therapies are administered, there are many possible explanations within the administered treatment that may account for the changes; a testable hypothesis would assist in disentangling the ‘active’ ingredient within the administered treatments. Moreover, rehabilitation therapies are often intended to address a wide variety of stroke-related impairment and disability problems, so a number of theories may need to be explicated.123

Although there is currently no consensus regarding definitions of acute, subacute, and chronic, with respect to time intervals, consideration should be given to the recovery changes that will occur following the stroke. Phases of recovery have been documented following stroke, and would suggest that the rate of spontaneous recovery of motor function is greater in the earlier time period post stroke and less at later points.124 Although, spontaneous recovery occurs less as the time interval from onset increases, there is good evidence that the neuroplasticity of the brain, is still responsive to practice-induced plasticity.124 This has implications for the onset and intensity of rehabilitation and possibly the duration of treatment. Additionally, it suggests that changes in therapy should be measured “serially” rather than being restricted to outcome assessment at baseline and endpoint. Researchers should therefore attempt to provide a rationale in the context of stroke recovery trajectory for the intensity and timing of their interventions, as well as the frequency and timing of the outcome assessments.

The role of the care provider is often pivotal in stroke rehabilitation interventions. The expertise of care providers needs to be described by providing information about professional qualifications, years in practice, and training in preparation for the study. The information about the intervention needs to include how the care provider interacts with the clients, the components of the intervention, the timing and intensity (how much, how often, when), and the expectations of effect on the client (level of participation, homework expectations). Patient engagement and motivation is a key factor that may affect the effectiveness of the rehabilitation therapy. There are a variety of methods that can be employed (e.g., self-efficacy techniques) to produce adequate or at least greater engagement. These methods are context dependent and, as such, some means of describing this may also be warranted in future evaluations of therapies. There is also the potential for ‘care provider’ effects, where the level of enthusiasm or the unique attributes of the care provider may account for some of the variation in treatment. Awareness and potential monitoring of these care provider effects is therefore warranted.

There needs to be information about how the intervention has been standardized, including care provider training and how the intervention will be monitored to ensure standard administration. This can be challenging in the context of some therapies, where some treatments may be individualized. In essence, the ‘treatment’ being evaluated is actually an algorithm of possible interventions that a therapist may individualize to a particular patient (e.g., being assigned to one of several possible treatments in the community to prevent falls). In the reporting of results (what actually happened), there needs to be detail about the actual administration of the intervention, including information about the care providers’ compliance with the intervention and the content, quality, and quantity received by the clients. In some study designs, where the comparator is usual care, the intervention is not described, but information needs to be documented about all aspects of the “normal” care and reported in the results. Rehabilitation treatments very often involve interaction with the external environment, such as training in a bathroom or kitchen. A description of the environment may also be important in these cases.123 Similarly, in rehabilitation, a number of services are delivered to stroke clients (e.g., acute inpatient stroke rehabilitation) and the ‘system’ or center within which they are delivered may also need to be described and understood. The intensity within each component of the service and the intensity of each service may be complex to describe and monitor.

Finally, heterogeneity within the stroke population should be considered. In addition to the variability of the type of stroke, there are a variety of other factors (such as comorbid conditions, age, social situation, etc.,) that contribute to this heterogeneity. Studies should adequately document these factors and explore their impact on stroke outcome responses to treatment. In other areas of health, there is a move towards identifying subgroups that show the greatest improvement following treatment. Exploring the characteristics of those who demonstrate a strong response to treatment will assist in matching the optimal therapies to maximize subsequent recovery.

## Methodological Issues from the Purposive Sampling

The majority of the abstracted studies were RCTs. Almost all of the published RCT manuscripts contained reports of randomization, but the in-depth review of two specific studies in each outcome domain showed that the reporting of randomization was inconsistent. The authors of some studies described the process of randomization (e.g., computer generated), while others reported the type of randomization (e.g., block). Reporting on the details of study samples was more consistent. Most of the authors described the source of their samples, the inclusion/exclusion criteria, and basic sample characteristics such as age and sex. Almost all RCTs contained a table showing comparisons of subjects in different treatment groups.

Approximately 75 percent of the abstracted RCTs contained a mention of blinding. However, the figure was only 50 percent for the cognition domain. The in-depth review of individual studies showed that blinding was difficult because of clearly identifiable differences in the interventions. Many authors were cognizant of the difficulties of blinding in stroke rehabilitation and they designed their studies so that patients and therapists were unaware of the hypotheses being tested; therapists in some studies were restricted to delivering only one of the treatments. Blinding was possible for the persons assessing outcomes, and many authors reported that their assessors were in fact blinded to treatment allocation.

Many of the treatments could only be delivered by a trained professional. Usually these persons were physical, occupational, or speech therapists, although sometimes nurses with training in specific procedures were also used to deliver interventions. About 75 percent of study authors reported the use of trained professionals to deliver interventions. Usually this reporting was a simple mention of the type of professional required (e.g., “speech therapist”); details of background and training were typically not provided in the published manuscripts.

The details of the interventions were clearly described in almost all of the studies. Many interventions were compared against a closely related derivative rather than standard practice. Many authors reported the frequency of the interventions (e.g., number of sessions) and the overall duration of therapy (except in the dysphagia domain, where only half of the authors reported this information). The in-depth review of specific studies suggested that much of the lack of reporting was likely due to space restrictions in journals. These restrictions prevented many authors from describing detailed treatment protocols. Authors tended to report the average number of sessions and the average duration of therapy for subjects in their studies.

Length of followup varied widely in the abstracted studies. Most followup periods fell within a short-term band of 1 to 12 months. In the in-depth review of specific studies, followup periods ranged from a few weeks to one year in studies of quality of life (QoL), activities of daily living (ADL), cognition, and speech. For ambulation and dysphagia, followups ranged from a few weeks to approximately 6 months.

The reporting of comorbidity and concomitant treatment was quite poor across all domains. Less than half of the abstracted studies contained reports of prior or concomitant treatment.

The psychometric properties of a majority of the instruments used in the studies obtained for the purposive sampling portion of the review were not reported, either in the studies themselves or in the review articles. In the case of the more frequently used instruments, reliability and validity had usually been proven to exist in stroke patient populations. Many of these instruments also had responsiveness to change demonstrated in stroke. Problem areas involved the minimal clinically important difference (MCID), study specific measures, and the communication and dysphagia domains. Virtually no information could be found on the MCID for any outcome measure. This can be problematic because differences between groups of study subjects on a scale score might be found to be statistically significant, but not clinically significant. Future research should consider the development of MCIDs for important instruments in stroke rehabilitation. Many outcome measures seemed to be instruments that were developed for a specific study. Some such instruments were questionnaires and others were clinical tests involving timed activities. No matter how intuitively appealing such instruments may appear they should not be assumed to be appropriate for use in stroke patients. Every instrument must first have its psychometric properties tested in stroke patients prior to use in the field of stroke rehabilitation. In the communication and dysphagia domains, there was no information on the psychometric properties of any of the outcome measurement instruments used in the purposive sampling studies. Again, psychometric properties should be assessed prior to the use of any instrument.

In the 12 studies (two per domain) that were subject to in-depth review, outcomes were generally measured using scales. Some dysphagia outcomes were measured clinically. For many of the scales, the psychometric properties were not tested in the stroke rehabilitation population.

Commentary – In-depth review of two studies per domain. The large number of RCTs, and the explicit attempts to describe randomization and blinding in some of the published trial reports, suggests that many researchers in stroke rehabilitation seek to implement the principles of high quality research design and evidence-based practice (EBP). However, several consistent themes emerged from the purposive sampling exercise and suggested potential areas of improvement for future studies in stroke rehabilitation. A few RCTs enrolled and randomized less than 10 subjects in total. The ability to draw any meaningful efficacy conclusions from such small studies is severely compromised by the obvious lack of power to detect effects and the high possibility of random sample error. Power is the probability of detecting a true effect in a study. Studies with larger sample sizes have higher power. Authors should enrol large enough samples to detect clinically significant effects, not just statistically significant effects. Authors should also be explicit in the methods with respect to their sample size calculations. Specifically, they should provide the MCID and justify their selection of such a difference. Few of the authors of the abstracted studies provided or justified a particular MCID. This may not inhibit the possibility of finding statistically significant results, but does not allow for the assessment of clinical significance.

Based on the published trial reports, there were no consistent errors that threatened the internal validity of the abstracted studies. Some studies were methodologically weak in certain areas, while other studies were weak in other areas. Descriptions of blinded assessors and the randomization process suggest that some authors made attempts to minimize bias and confounding. However, many authors reported only rudimentary patient data, which were often limited to a few variables such as age, sex, and education. Comorbidity and concomitant treatments were often not reported. In an RCT with proper randomization, this is less of a concern because the randomization should create comparable treatment groups, thus cancelling the effect of any confounding due to comorbidity and concomitant treatment. In observational studies, though, confounding could occur if the treatment groups differ on these (or other) characteristics. Therefore, it is especially important for the authors of observational studies to present the details of all possible confounders when they report sample characteristics. In this way, the readers of the studies will be able to assess whether the study groups are comparable to one another.

Notwithstanding the issue of confounding in RCTs versus observational studies, the authors of RCTs should also provide a complete description of the study sample. This lends itself to establishing generalizability. Strict inclusion and exclusion criteria in many RCTs exclude persons with common comorbidities and concomitant treatments. Full disclosure of sample characteristics is required so that readers of trial reports can assess whether the subjects in an RCT are representative of a particular group of patients. If they are not representative, then the findings of the RCT may not be applicable to that particular group.

Length of followup also requires careful consideration in future studies of stroke rehabilitation therapies. Improvements to cognition and communication may take months, even years, so studies should be long enough to assess these outcomes. In the abstracted studies under the cognitive domain, followup generally lasted for less than 1 year. Under speech, two studies had 5 year followups and the remainder had followups of 1 year or less. For studies in the other domains, followup lasted for periods of days to months (12 months typically maximum). For ambulation, short followups are generally adequate due to the relatively rapid recovery periods for motor function and gait. Followups for QoL are less amenable to precise time specification because QoL itself involves a subjective component that may be independent of improvement in any one domain. For example, patients with long-term stroke-related disabilities may have accepted and adjusted to their conditions. Consequently, they may rate their QoL higher than patients with less severe disabilities. Ideally, QoL should be measured at the same time points as the primary outcome. ADLs, like cognition, can improve over time. This would suggest medium- to long-term followup. In the abstracted ADL studies, followup times averaged 12 months or less. The dysphagia studies tended to focus on interventions that would allow patients to begin adapting to swallowing problems, rather than on interventions that would correct the problems. Therefore, the dysphagia studies typically lasted for periods of weeks, which was long enough to assess whether the interventions would help patients adapt.

The authors of many studies examined a variety of different outcomes. In some studies, one outcome was specified as the primary outcome, while in others there was no named primary outcome. The use of many outcomes reflects the multifaceted nature of both the sequelae of stroke and the impact of the interventions. However, rehabilitation programs and devices are usually designed to make an impact on a narrow band of outcomes, with additional effects on other outcome areas being a ‘spin-off’ of the main impacts. For example, a novel therapeutic technique may be designed to improve speech following stroke. This technique may concomitantly improve QoL as a patient’s ability to communicate improves. The most immediate and therefore primary outcome, though, would be the improvement in speech. Sample size calculations in stroke rehabilitation studies should be based on the primary outcome to ensure that important inter-group differences can be detected in the study.18,19

Many of the outcome measurement instruments used in the abstracted studies were not assessed for reliability and validity in persons undergoing stroke rehabilitation. Similarly, there were few assessments for responsiveness to change and MCID in stroke. Researchers should make every attempt to employ outcome measurement instruments that have been validated in stroke patients. It is not sufficient to rely on the most popular instrument without consideration of psychometric properties because an often used, invalid instrument will produce invalid results.

Recent work on linking ICF domains to stroke rehabilitation20 has produced a ‘brief core set’ of 18 ICF categories that reflect the spectrum of problems in persons who have suffered a stroke. Other researchers8 have slotted popular outcome measurement instruments into the various categories of the core set. The ICF core set and slotted instruments can serve as guides to help researchers focus on the most important outcomes in stroke rehabilitation. However, this agreed-upon focus is not a substitute for judgment. Researchers should still select a primary outcome that reflects the major thrust of the therapy in question; specific outcome measures should have good psychometric properties in stroke rehabilitation. It is not sufficient to select from a ‘grab-bag’ of outcomes and instruments based solely on their appearance on a list.

## Methodological Issues From the Review of Reviews

We undertook a review of reviews as an additional means to evaluate the quality of studies within the broad area of stroke rehabilitation. We found a large number of systematic reviews were available even after limiting the publication date to 2005 forward. Additionally, we found that approximately half of these were Cochrane reviews, which suggested that there were a significant number of randomized trials being undertaken in stroke rehabilitation.

In general, the quality of the majority of the systematic reviews was high, scoring greater than 14 on our quality assessment criteria. It was recognized that some methodological flaws within these systematic reviews may be related to incomplete reporting rather than to a lack of rigour in the methods. The quality of the individual studies was generally judged positively within these systematic reviews, but there was great variation in the criteria used to judge the adequacy of the studies evaluated.

The individual trials in stroke rehabilitation, regardless of therapy, for the most part did not have blinded patients or healthcare providers, but did have blinded outcome assessors. Adequate randomization and allocation as well as adequate accounting for all subjects continued to be a problem in many trials. Few of the systematic reviews evaluated the comparability of groups at baseline, the potential for adverse events, or problems with contamination and co-intervention. In this regard, it is difficult to generalize regarding methodological problems within any of the trials being evaluated in a review. These three factors do affect internal validity and would be important to evaluate in future trials within systematic reviews.

When considering the population characteristics being evaluated in the trials, the variation in the study populations evaluated may reflect that some therapies are logically restricted to specific phases of stroke rehabilitation; however there were a fair number of interventions that were directed to all phases of the recovery continuum and the rationale for this was not always adequately presented. When considering the sample sizes within these trials, there was great variation, but in general they were not large relative to drug trials. As noted previously in the purposive sampling, adequate sample size is related to power and the ability to detect differences amongst groups; this is particularly relevant for studies selecting multiple outcome measures.

The systematic reviews evaluating the use and classification of outcomes used in the treatment of stroke patients were consistent in their recommendations. Although, the evaluation of these outcomes was not restricted to “rehabilitation” studies per se, the conclusions were applicable to this phase of intervention. Most of the reviews on outcomes used in stroke patients, noted that some outcomes frequently used in the studies had not had psychometric properties established for stroke patients. In general, there was some concern with potential difficulties with instruments that are self or interviewer administered questionnaires being applied to stroke patients (due to deficits in cognition and communication). Additionally, at least one review pointed to the timing of outcome assessment, suggesting that the rationale for the interval to measure outcomes during the recovery process was in need of greater refinement (particularly in light of the natural history of stroke recovery). The interval for measuring outcomes also speaks to issues of responsiveness of the instruments relative to when change is likely to occur. The selection of appropriate intervals to evaluate patients is difficult but important to address and justify in future research.

All the systematic reviews on outcome measures in stroke rehabilitation would support the use of overlap across types of measures (generic versus disease specific) and domains covered within the outcomes selected. In the former case, it was clear that no single measure would capture all the important attributes (considering the ICF framework) to evaluate within stroke patients; as such the recommendation was to include multiple outcomes to cover the breadth of functions or alternatively to develop new and more comprehensive measures. The core set of ICF functions proposed20 would be an initial, universal frame of reference to assist in selecting a minimum set of functions to be considered when selecting outcome measures for evaluating the efficacy of studies. However, there is still some consensus work to be undertaken to determine the level of detail for the specific activities identified. For example, although walking has been identified as a core function important for persons with stroke, it is not clear if only walking indoors (as opposed to walking outdoors) should be evaluated following stroke rehabilitation.

## Conclusion

The methodological quality of studies in stroke rehabilitation was reviewed in accordance with the components of the key question. Researchers in the field recognize the benefits of investigating interventions using the RCT design, but the reporting of randomization methods and comparability between groups was lacking in some instances. Blinding is difficult to conduct in stroke rehabilitation studies because the nature of the interventions is obvious to patients and healthcare providers alike. Many researchers in stroke recognize these limitations and try to balance the rigor of adequate blinding and the feasibility of applying the interventions.

Major methodological problems involved sample size and the psychometric properties of outcome measurement instruments. Sample size was sometimes too small to have adequate power to detect meaningful effects. Many authors failed to show sample size calculations or report an MCID. For many of the instruments used to measure outcomes, the psychometric properties in the stroke population were not tested.

The road forward looks positive regarding the methodological quality of studies in stroke rehabilitation. However, despite some high quality research that conforms to the principles of EBP, there is still room for improvement, especially in the areas outlined above.

The review of reviews showed that most systematic reviews were undertaken with adequate rigour and presented the evidence for stroke rehabilitation adequately. Many of the reviews evaluated high level study designs (e.g., randomized trials); however, not all of these trials were conducted in a sufficiently rigorous manner. Most systematic reviews evaluated methodological aspects of the eligible studies with standardized checklist or criteria. The majority of reviews evaluated randomization, blinding, and withdrawals/dropouts. Fewer reviews evaluated baseline comparability, evaluation of adverse events, and co-intervention or contamination. Many reviews indicated that blinding of the patient and the provider was not possible in stroke rehabilitation and as such did not evaluate eligible studies for this criterion. These findings concur with those of the purposive sampling.

Our review of reviews on outcome measures in stroke showed that a variety of outcomes have been used to measure the same attributes of interest within studies of rehabilitation interventions in persons with stroke. Currently, no single outcome measure captures all relevant dimensions of important attributes of interest to patients and clinicians. This implies that multiple measures may need to be included to capture all these important domains. Moreover, there is a need to determine the degree of comprehensiveness required when evaluating some of these outcomes of interest.

All reviews on outcome measures in stroke recommended that future studies evaluating rehabilitation therapies in stroke patients should select outcome measures that have established psychometric properties (reliable, valid, and responsive). Additional consideration should also be given to the potential for floor and ceiling effects and practical administration issues. Moreover, the timing of outcome measurement should be justified, with some consideration of the natural history of stroke recovery. These findings also concur with those of the purposive sampling.