# Results

## Purposive Sampling

Overall, a total of 1,674 citations were retrieved in the literature search. After vetting all citations for applicability of inclusion/exclusion criteria at level one screening (title and abstract), citations encompassing more than one of the six outcome domains were categorized according to primary outcome domain. A total of 126 citations (7.5 percent) passed level one screening, although four did not get forwarded to level two screening (data abstraction phase) because they were outside of the range of the 20 most recently published articles in their respective domains. During data abstraction, 11 citations were excluded because of a failure to meet the inclusion/exclusion criteria, leaving a total of 99 abstracted studies. The flow of studies through the screening and abstraction process is shown in Table 1.

Table 1 Flow of purposive sampling studies through data screening and abstraction

| Ambulation | Quality of Life | Activities of Daily Living | Cognition | Communication | Dysphagia
Total citations screened | 165 | 200 | 184 | 522 | 332 | 271
Passed level one screening | 30 | 21 | 23 | 21 | 17 | 14
Not retrievable | 0 | 1 | 0 | 0 | 0 | 0
Not forwarded to level two screening^*^ | 4 | 0 | 0 | 0 | 0 | 0
Forwarded to level two screening (data abstraction) | 26 | 20 | 23 | 21 | 17 | 14
Total duplicates with other domains | 6 | 3 | 10 | 2 | 1 | 0
Duplicates screened in primary domain at level 2 | 0 | 2 | 7 | 1 | 1 | 0
Duplicates moved to another domain for level 2 screen | 6 | 1 | 3 | 1 | 0 | 0
Excluded level two | 1 | 2 | 0 | 2 | 4 | 2
Passed level two screening | 20 | 17 | 20 | 18 | 12 | 12

* Not within the range of the 20 most recently published studies that met the inclusion/exclusion criteria

Since the objective was to obtain the 20 most recently published studies in each outcome domain (within the years searched), provided the studies met the inclusion/exclusion criteria, four ambulation studies that were beyond this range were not forwarded to level two screening. In the case of communication and dysphagia, the number of studies that passed level one screening did not reach the initial threshold of 20.

The characteristics of all abstracted studies are shown in Appendix Tables B to D. Prior to describing the methodologically superior and methodologically inferior studies in each outcome domain, a brief summary of the key characteristics of all abstracted studies will be provided below.

Study design. The vast majority of abstracted studies (>88 percent) were Randomized Controlled Trials (RCTs) (Figure 4). The highest percentage of RCTs was in the activities of daily living group (ADL) (100 percent); the lowest percentage was in the dysphagia group (67 percent). From the viewpoint of evidence-base practice (EBP), good quality RCTs form the highest possible level of evidence for or against a therapeutic intervention (Figure 3).

Figure 4 Number of abstracted studies by study design

Figure 4. Number of abstracted studies by study design

Patient selection. All except two abstracted studies reported inclusion and exclusion criteria and at least rudimentary sample characteristics such as age and sex (Figure 5). This information is needed to determine the group of people to whom a study’s results apply, as well as to help judge whether the results can be generalized to populations beyond the actual group of people in the study. The examination of sample characteristics can also provide an indication of the presence of selection bias. For example, if a certain stroke rehabilitation therapy is known to be most efficacious in persons over 50 years of age, but the study sample is primarily composed of persons 50 years of age and under, then poor therapeutic results could be attributed to sample selection factors, rather than to the therapy itself.

Figure 5 Number of abstracted studies reporting inclusion/exclusion criteria and patient characteristics

(both=report both; one=report one only)

Figure 5. Number of abstracted studies reporting inclusion/exclusion criteria and patient characteristics (both=report both; one=report one only)

Randomization and blinding. Two essential elements of an RCT design are randomization and blinding. Randomization should ensure that the various treatment groups are comparable to one another on all factors except the therapy of interest. Blinding helps to prevent knowledge of the therapy from influencing how subjects are treated and assessed during the course of a trial. The authors of virtually all of the abstracted RCTs reported that their subjects were randomized to treatment (Figure 6a). Similarly, a majority of authors in all except the cognition domain reported that some type of blinding was pursued in their studies (e.g., blinding of outcome assessors [Figure 6b]). The reporting of randomization and blinding is seen as an essential feature to earmark the quality of an RCT.35

Figure 6a Percentage of abstracted RCTs reporting patients were randomized

Figure 6a. Percentage of abstracted RCTs reporting patients were randomized

Figure 6b Percentage of abstracted RCTs reporting patients were blinded

Figure 6b. Percentage of abstracted RCTs reporting patients were blinded

Providers. An important aspect of stroke rehabilitation therapy is the professional background of the person administering the therapy. In many instances, trained occupational, physical, or speech therapists are required to successfully deliver a therapy. The authors of studies in the field of stroke rehabilitation should therefore specify, as part of the description of the therapy under evaluation, the required professional qualifications of the person(s) who administer the intervention(s). In the abstracted studies, the majority of authors mentioned the type of health professional that was required to administer a therapy (Figure 7). Studies that omitted specific mention of professional status generally reported that rehabilitation interventions were delivered by a rehabilitation team, medical doctor, or one of the study researchers.

Figure 7 Percentage of abstracted studies reporting the type of provider of therapy

Figure 7. Percentage of abstracted studies reporting the type of provider of therapy

Timing of post-stroke initiation of intervention. An important aspect of any rehabilitation therapy is the timing of its initiation post-stroke. Some therapies may need to be started as soon as possible after the stroke event, while others can be initiated weeks or months later without any deleterious impact on efficacy. To foster a clear understanding of how an intervention is supposed to work, and to judge whether the intervention(s) in a specific study are being applied properly, the authors should report the timing of initiation of therapy. In the abstracted studies, all of the authors in the ambulation domain reported the timing of initiation. In the other five domains, 65 percent of the authors reported the timing (Figure 8).

Figure 8 Timing of intervention in abstracted studies

Figure 8. Timing of intervention in abstracted studies

Frequency and duration of intervention. As with the issue of timing, the frequency and duration of an intervention should be reported to foster an understanding of the intervention and judge the appropriateness of its use in a study. In all except the dysphagia domain, most of the studies contained reports of both the frequency and duration of the interventions. In the dysphagia studies, only half contained reports of both items (Figure 9).

Figure 9 Number of abstracted studies reporting frequency and duration of intervention

(both=report both; one=report one only; none=report neither)

Figure 9. Number of abstracted studies reporting frequency and duration of intervention (both=report both; one=report one only; none=report neither)

Length of followup. The length of followup in any study must be long enough to allow the therapy to work and long enough to allow for the development of outcomes. Given the wide variability in profiles of stroke patients, as well as in prognosis, it is difficult to establish minimum followup times for any specific outcome domain (or outcome measure). However, authors should report lengths of followup so that readers can assess the applicability of a study’s results to specific groups of patients. In the abstracted studies, lengths of followup varied widely, although they typically fell within a band of 1 to 12 months. The authors of eight studies did not report length of followup (Figure 10).

Figure 10 Timing of followup in abstracted studies

Figure 10. Timing of followup in abstracted studies

Prior and concomitant treatments. As was the case with patient selection, subjects’ receipt of prior or concomitant treatment should be reported to determine the applicability and generalizability of study results to various groups of subjects. Less than half of the abstracted studies contained reports of prior or concomitant treatment (Figure 11), making this the least often reported key characteristic of the studies.

Figure 11 Number of abstracted studies reporting prior/concomitant treatment

(no=subjects did not receive prior/concomitant treatment)

Figure 11. Number of abstracted studies reporting prior/concomitant treatment (no=subjects did not receive prior/concomitant treatment)

Standard treatment clearly described. Virtually every study reported details of the standard treatment. For example, they reported what was done to patients as part of standard rehabilitation therapy. The communication of these details allows readers to evaluate whether the standard treatment was an adequate comparator against the therapy of interest. No figure is provided because almost all studies contained information about the standard treatment.

Outcome measurement instruments. At least 20 different outcome measurement instruments were used in each domain (see Appendix D). Some of these instruments were well-established scales such as the Barthel Index1 and others were vaguely described tools such as a “swallowing questionnaire”.2 In the ambulation, Quality of Life (QoL), ADL, and cognition domains, the most frequently used instruments were reliable and valid in stroke patients. Some of these instruments were also responsive to change in stroke patients. There was very little information on the minimum clinically important difference (MCID) for any of the instruments. In the communication and dysphagia domains, there was no information on any psychometric properties for any of the instruments. Figure 12 shows the number of instruments in the ambulation, QoL, ADL, and cognition domains for which information was provided on psychometric properties. The communication and dysphagia domains are omitted from the figure due to the aforementioned lack of information.

Figure 12 Number of instruments in stroke in four outcome domains with information on psychometric properties

(MCID=minimum clinically important difference)

Figure 12a Ambulation (n = 45 instruments).

Figure 12a. Ambulation (n = 45 instruments)

Figure 12b QoL (n = 54 instruments).

Figure 12b. QoL (n = 54 instruments)

Figure 12c ADL (n = 25 instruments).

Figure 12c. ADL (n = 25 instruments)

Figure 12d Cognition (n=36 instruments)

Figure 12. Number of instruments in stroke in four outcome domains with information on psychometric properties (MCID=minimum clinically important difference)

In the four outcome domains for which graphical data are reported, the instruments were found to map onto one of three international classification of functioning (ICF) domains: activity, function, or participation. Figure 13 shows a breakdown of instruments by ICF domain, stratified by outcome domain.

Figure 13 Breakdown of instruments by ICF domain

Figure 13a Ambulation (n=45 minutes)

Figure 13a. Ambulation (n=45 minutes)

Figure 13b QoL (n = 54 instruments)

Figure 13b. QoL (n = 54 instruments)

Figure 13c ADL (n = 25 instruments)

Figure 13c. ADL (n = 25 instruments)

Figure 13d Cognition (n = 36 instruments)

Figure 13d. Cognition (n = 36 instruments)

It should be noted that the assessment of each instrument’s psychometric properties in stroke was based on whether the authors who used the instrument actually discussed psychometric properties in the methods sections of their study reports. Additional information on the presence or absence of psychometric properties in stroke was gleaned from information presented in the systematic review articles3–6 and two reviews of outcome measures.7,8 These data formed the source of information for the tables in Appendix D. Primary sources (studies introducing and validating the instruments themselves) were not consulted for this exercise.

With respect to the above summaries, there are several important methodological points to consider when evaluating studies in stroke rehabilitation. These points are listed below to act as a frame of reference for the salient features that will be discussed in the specific study descriptions that follow. The important methodological points are:

1. RCTs or high-quality observational studies (e.g., cohort, case control studies) are the ideal type of study design;
2. The sample characteristics of subjects should be presented in a table (stratified by treatment group);
3. Inclusion and exclusion criteria should be clearly listed in the study methods;
4. Details of randomization and blinding should be reported in the studies;
5. Authors should describe the type of professional needed to provide the therapy;
6. Authors should report the timing, frequency, and duration of the interventions in their study;
7. Authors should report the length of followup;
8. Authors should report any prior or concomitant treatments received by study subjects;
9. The comparator treatment should be clearly described; and
10. Outcome measurement instruments should only be selected if they have strong psychometric properties in stroke patients (reliability, validity, responsiveness to change).

### Purposive Sampling – Domain-Specific Study Descriptions

Ambulation. The most methodologically sound study in ambulation was an RCT conducted by Marigold et al.60 to compare two different community-based exercise programs (i.e., agility versus stretching/weight-shifting) to improve balance, mobility, and standing postural reflex (see Appendix B: Table B1 and Appendix C: Table C1). The sample was clearly described and compared to persons who dropped out of the study. The timing, frequency, and duration of both interventions, as well as the length of followup, were clearly described. Outcome assessors were blinded, the persons responsible for conducting the exercise programs (physical and recreational therapists, kinesiologists) were aware of subjects’ group assignments, but not the study outcomes, and subjects themselves were aware that they were in one of two exercise programs, but they were unaware of the differences between programs. The authors described subject comorbidities and concomitant use of assistive devices. The primary outcome measure was the Berg Balance Scale,61,62 which has demonstrated good reliability and validity in ambulation in stroke rehabilitation.

The study with the least rigorous methodology in ambulation was a cohort study by Roerdink et al.63 The study was conducted to examine the efficacy of acoustically-paced treadmill walking to improve gait coordination in people after stroke (see Appendix B: Table B1 and Appendix C: Table C1). The ‘exposed’ group consisted of 10 volunteers who suffered a first-ever ischemic cerebrovascular accident within 3 to 104 months of joining the study. The ‘unexposed’ group (n = 9) was reported to be similar to the intervention group on age, height, and weight, although the authors do not mention how they were recruited. Although it appears that exposure status was based on prior or no prior stroke, the authors did not report whether the unexposed group had any history of cerebrovascular events. Furthermore, the authors did not report the source population of the study subjects, nor whether these subjects had comorbidities or concomitant treatments. The absence of detail makes it difficult to assess the potential for selection bias. Additionally, it is difficult to ascertain whether the two groups are comparable. In the study, both groups of subjects received the treadmill intervention, which was generally well described in terms of procedure (e.g., belt speed settings). However, the timing, frequency, and duration of the intervention were not reported in the article. The authors took various measurements of stride (frequency, length, time, width) on the treadmill and compared the exposed and unexposed groups. Not surprisingly, the exposed (stroke) group performed worse on these measures than the unexposed (non-stroke) group. The authors then measured the stride parameters on the stroke patients only, stratified by treadmill pace. None of these analyses provide answers as to whether the acoustically-paced treadmill improves gait coordination in stroke patients. This issue would have best been resolved with a comparison treatment. The exposed-unexposed comparison might in some cases be a useful means of establishing a healthy, baseline treatment ceiling with which to evaluate the progress of stroke patients. In this study, though, the utility of comparing exposed and unexposed groups is questionable because there is a lack of reported detail on the degree to which these groups may be similar to one another.

Quality of life. The study by Park et al.64 is a well-designed research effort to examine QoL in stroke rehabilitation (see Appendix B: Table B2 and Appendix C: Table C2). The study is an RCT to investigate real versus sham acupuncture to improve post-stroke QoL. The randomization is clearly described (i.e., block randomization), as are the source and basic characteristics of the sample. However, the authors do not mention whether the sample is receiving concurrent treatment, nor is comorbidity clearly described. The real and sham acupuncture interventions are both well-described and the post-stroke timing, frequency, duration of treatment, and length of followup are clearly reported. The authors wrote that all patients received “conventional multidisciplinary stroke rehabilitation” (p.2027) in addition to real or sham acupuncture. While no details of conventional therapy were provided, this is not a serious methodological flaw (in this case) because conventional therapy was not the comparator treatment. If the randomization was conducted properly, then any potential confounding effects of conventional therapy would be evenly distributed across the treatment groups. Even distribution of confounders negates problems with confounding. In this study, patients and physicians were blinded as to treatment, and outcomes were assessed using the EQ-5D, which has been validated for use as a measure of QoL in stroke.65–67 The two-week followup period might be too short to assess the impact of acupuncture on medium- or long-term QoL.

In contrast to the Park et al. study,64 the research by Hafsteinsdottir et al.68 was a cohort design where ‘exposed’ subjects received neurodevelopmental treatment (NDT) and ‘unexposed’ subjects did not (see Appendix B: Table B2 and Appendix C: Table C2). The authors clearly describe the sample (source of subjects, sample characteristics, disease history), but they do not explain NDT in clinical terms. The authors also do not explain the comparator treatment, nor do they provide the timing, frequency, or duration of treatment. No mention is made of blinding. QoL is measured using the 30-item, stroke-adapted, Sickness Impact Profile (SA-SIP30)69 and a self-reported visual analogue scale, which was developed for use in stroke.70 The lack of detail on NDT and the comparator therapy, as well as the absence of information on the timing of the interventions, means the precise conditions under which NDT may or may not show an effect are not clear. The clinical suitability of NDT can only be judged if more precise information is given.

Activities of daily living. One of the better ADL studies, by Langhammer et al.,71 examined whether two different strategies of physical exercise would have a differential impact on maintenance or improvement of ADL (see Appendix B: Table B and Appendix C: Table C3). The study was an RCT, but randomization was carried out inappropriately using a die toss rather than a computer-generated sequence. Despite the improper randomization, the treatment groups were similar to one another on basic sample characteristics such as age and sex, but no mention was made of comorbidities or concomitant treatments. The specific exercise regimens for both treatment groups were described, as was the timing, frequency, and duration of treatment. The study was double-blind, with patients and researchers being unaware of treatment assignment. ADL outcome was measured with the Barthel Index, which has good psychometric properties in the field of stroke rehabilitation.72

A study by Gilmore and Spaulding73 was an RCT where 10 subjects were randomized to receive occupational therapy with video feedback or occupational therapy with verbal feedback (see Appendix B: Table B3 and Appendix C: Table C3). The source of subjects was clearly described, but only rudimentary data (i.e., age, sex) was provided about the subjects themselves. The interventions and frequency of interventions were well described, but the post-stroke timing and duration of interventions were not. Each subject received a maximum of 10 sessions, but the interval between sessions and the total elapsed time between first and last session were not reported. The outcome was measured on two portions of the Klein-Bell Activities of Daily Living Scale,74 which is used often in stroke rehabilitation studies even though its reliability and validity have never been formally assessed in this area. The portions of the Klein-Bell scale that were used in this study were the socks and shoes subtests, which measure patients’ ability to don socks or shoes. The validity of separating these two subtests from the entire scale has never been assessed by researchers. Given the validity issue, it is possible that the observed results were biased due to an inappropriate outcome measure. Also, the very small sample size may have produced random error, thus leading to a further bias of results.

Cognition. Westerberg et al.75 conducted a pilot RCT to investigate the impact of computerized working memory training on cognition in 18 persons who had a stroke within the previous 12 to 36 months (see Appendix B: Table B4 and Appendix C: Table C4). The source of the study sample was clearly described, although the authors did not specify whether all patients who fell within the 12- to 36-month timeframe were considered for enrollment. The number of dropouts during the trial was given (n = 6), as were the reasons behind the dropouts. The authors did not report subjects’ comorbid disorders. The timing, frequency, and duration of the working memory intervention, as well as the tasks composing the intervention, were clearly described in the published study report. Length of followup was also reported. The study was described as randomized, but the text contains no description of the randomization procedure. Outcome assessors were not blinded after the baseline assessment. Eight different neuropsychological tests were used to measure cognition in the study. The authors did not report whether any of these tests had adequate psychometric properties in stroke patients. Persons in the control group did not receive any sort of working memory training. The authors did not report whether the study subjects received any sort of concomitant treatment.

Cherney et al.76 studied visual scanning versus oral reading in the treatment of unilateral neglect (Appendix B: Table B4 and Appendix C: Table C4). Four subjects were randomized to the scanning or reading groups. Subjects were enrolled at least 7 months post-stroke; the authors report age, sex, and education data, but not data on comorbidity or concomitant treatment. The authors also do not report the source of subjects. The visual scanning and oral reading procedures were well described, although the intervals between the 20 treatment sessions, as well as the interval between the first and last session, was not reported. Unilateral neglect was measured with the Mini-Mental State Examination (MMSE)54 and the Stroop Neurospychological Screening Test.77 The MMSE has not been validated in stroke rehabilitation;78 no sources could be found to indicate whether the Stroop Test has been validated in stroke rehabilitation. The authors found no differences between interventions. This may not have anything to do with the interventions themselves, but may instead be a reflection of the low power due to the small sample size.

Communication. Thorsen et al.79 compared home versus conventional stroke rehabilitation in 54 patients, 5 years after the study intervention was complete (see Appendix B: Table B5 and Appendix C: Table C5). The authors refer readers to an earlier publication to obtain information on sample characteristics and randomization. Details on the rehabilitation interventions are scarce. The authors report the mean duration and mean number of home visits for the home rehabilitation program, but do not provide details on the conventional rehabilitation program. The length of followup is 5 years, which is helpful in capturing the range of likely changes in subjects’ communicative abilities. However, it may have missed interim differences between groups. Outcome assessors were blinded as to the intervention. The specific outcome was aphasia, measured using the Reinvang Aphasia Test.80 This test measures fluency, naming, comprehension and repetition, as well as writing and reading. There was no literature cited to suggest whether this instrument had been validated in stroke patients.

Rochon et al.81 conducted a study to investigate the utility of mapping therapy on sentence production and comprehension (see Appendix B: Table B5 and Appendix C: Table C5). They randomized five patients who were at 2 to 9 years post-stroke and assessed outcomes using a battery of instruments (e.g., Caplan and Hanna’s Sentence Production Test).82 The authors clearly described each instrument, but failed to indicate whether the instruments were reliable and valid in stroke patients. The authors describe the mapping therapy in detail, but do not explain the control therapy. Information on the timing, frequency, and duration of the interventions are presented as averages across all five subjects. There is no mention of blinding. The authors report the source of the study subjects, as well as some basic subject data (age, sex, education, years post-stroke, etiology, dominant hand).

Dysphagia. Goulding et al.83 used a RCT to investigate whether a viscometer or standard practice (i.e., thickening of fluids by nurse) would lead to improved management of dysphagia in stroke patients (see Appendix B: Table B6 and Appendix C: Table C6). The source of subjects and rudimentary sample characteristics were reported. Subjects were randomized by a computer-generated algorithm and the number of withdrawals and dropouts were reported. The interventions and their frequencies were clearly described. Clinical outcomes (i.e., pulmonary aspiration, pulse oximetry) were used to measure the success of the viscometer versus standard practice. A single, blinded assessor conducted the clinical evaluations.

Huang et al.84 studied the frequency of aspiration pneumonia in patients fed by a family member versus patients fed by a trained nurse (see Appendix B: Table B6 and Appendix C: Table C6). Family members were shown a videotape of general nursing information and the nurses trained patients in various swallowing techniques. The authors mention that patients were recruited into the study within 24 hours of suffering a stroke. Feeding began within this time, but neither the frequency of feedings nor the length of followup are reported. No patient characteristics are provided. The study was non-randomized and patients recruited from January 2000 to July 2003 were fed by family members, while patients recruited from August 2003 to March 2005 were fed by the nurse. Aspiration pneumonia was assessed clinically by the presence of three or more of the following criteria: fever (temperature >38°C); productive cough with purulent sputum; abnormal respiratory examination; abnormal chest radiograph; isolation of a relevant pathogen (positive Gram stain or culture); or arterial hypoxemia (partial pressure of oxygen <9.3 kPa). Outcome assessors were not blinded.

### Systematic Reviews of Interventions in Stroke Rehabilitation

The search for systematic reviews yielded at total of 949 English language citations for initial screening. After evaluation at the first level of title and abstract screening, 204 citations were eligible for full text review. From these 78 were excluded because the rehabilitation intervention evaluated drugs used primarily to achieve medical stability for acute stroke rather than rehabilitation. From 126 eligible reviews evaluated at full text, 88 were excluded primarily because they: 1) were not systematic reviews, 2) were review of reviews, or 3) had a year of publication prior to 2005 (see Figure 14). In addition to reasons of feasibility, we focused on reporting from more recent systematic reviews as these would likely include the greatest number of studies, and reflect more current research within stroke rehabilitation. After full text screening, a final set of 38 systematic reviews evaluating the efficacy of various interventions were eligible for full data extraction. We further categorized the systematic reviews into those published within the Cochrane Database of Systematic Reviews (n = 18) and those that were not (n = 20). Those within the Cochrane systematic reviews were grouped separately, as these reflected a more standardized methodology, and internal peer review process. In addition, Cochrane reviews have detailed protocols for reporting the findings of the reviews and do not have limitations in the length of their publications. Thus, the Cochrane reviews (which are available through the Cochrane database) differ in their detail and format relative to reviews published in traditional journals. Evidence tables detailing the review search strategy, the eligibility criteria, populations evaluated, interventions reviewed, method of quality assessment, outcomes, and study results are found in Appendix E.

Figure 14 Flow diagram of eligible systematic reviews

Flow chart

Table 2, located at the end of this section, shows the types of interventions, the number of studies and their design, the total sample evaluated and the acuity of the stroke patients evaluated. A large variety of stroke interventions were evaluated. The Cochrane reviews are predominantly based on randomized, quasi-randomized (method of allocation is known but not random), or controlled clinical trials (randomization is not specified but cannot be ruled out). The number of eligible trials included in the reviews ranged from zero to 31 trials. The number of subjects evaluated within the Cochrane systematic reviews varied from 18 subjects to 6,936, not including the review where no trials were eligible. Most studies evaluated subjects with different acuity levels. There were studies that had a more homogeneous population, and these tended to include the population most likely to benefit from the specific intervention. The non-Cochrane reviews had a wider variety of eligible study designs including case series and case reports. The number of studies evaluated varied from three case reports to 29 mixed design studies; similarly the populations varied from three to 125,453 stroke patients (Table 2). Most reviews evaluated patients with mixed acuity levels.

Table 2 Summary of systematic review interventions and acuity of stroke populations

| Intervention | Types of Studies | Total Number Subjects | Stroke Acuity Acute (t≤3m), Subacute (3m<t≤6m), Chronic (t>6m)
Cochrane Reviews
Ada 2005^99^ | Devices for shoulder subluxation | 4 RCT | 142 | acute
Bennett 2005^100^ | Hyperbaric oxygen therapy | 3 RCT | 106 | acute
Bowen 2007^101^ | Cognitive rehabilitation for spatial neglect | 12 RCT | 306 | mixed
Brady 2006^13^ | Oral care/hygiene | 1 RCT | 67 | chronic
Discharge Trialists 2005^85^ | Services for reducing duration of hospital care | 11 RCT | 1597 | acute
French 2007^12^ | Repetitive task training for improving functional ability | 14 RCT/QRCT | 680 | 8 acute 2 subacute 4 chronic
Legg 2006^102^ | Occupational therapy | 9 RCT | 1258 | 8 acute & subacute 1 chronic
Mehrholz 2007^103^ | Electromechanical and robotic-assisted gait training devices | 8 RCT/CO | 414 | 8 subacute, 2^nd^ stroke
Moseley 2005^104^ | Treadmill training | 15 RCT/QRCT | 622 | 10 acute 2 subacute 2 chronic
Nair 2007^105^ | Cognitive rehabilitation – memory retraining | 2 RCT | 18 | 1 subacute 1 mixed
Pollock 2006^15^ | Physical therapy treatment approaches | 18 RCT 2 QRCT 1 SSRD | 1087 | mixed
Pomeroy 2006^98^ | Electrostimulation delivery to the peripheral neuromuscular system | 24 RCT | 888 | mixed
StrokeTrialists’ 2007^14^ | Inpatient stroke unit care vs. alternative forms of care | 24 RCT 7 CCT | 6936 | 30 acute 1 up to 12m
Thomas 2008^106^ | Optimal methods for treating urinary incontinence post stroke | 12 RCT/QRCT | 724 | mixed
West 2005^90^ | Apraxia of speech interventions | None | NA | NA
Woodford 2007^107^ | EMG biofeedback for motor function recovery | 13 RCT/QRCT | 269 | 2 acute 3 subacute 7 chronic 1 trial – not specified
Wu 2006^108^ | Acupuncture | 5 RCT | 368 | chronic
Zhang 2005^109^ | Acupuncture | 14 RCT | 1208 | acute
Non-Cochrane Reviews
Ada 2006^91^ | Strengthening interventions (i.e. biofeedback, electrical stimulation, muscle re-education, progressive resistance exercise, and mental practice) | 21 RCT/CCT | 768 | 10 acute 1 subacute 10 chronic
Bjorklund 2006^110^ | Constraint-induced therapy | 11 mixed | 179 | 2 acute 2 subacute 2 subacute/chronic 5 chronic
Bonaiuti 2007^111^ | Constraint-induced therapy | 9 RCT | 243 | 1 acute 3 subacute 5 chronic
Braun 2006^16^ | Mental practice | 4 RCT 1 CCT 2 CS 3 CR | 121 | 2 acute 4 subacute 4 chronic
Carson 2005^112^ | Hyperbaric oxygen therapy | 4 RCT 1 CCT 17 OS | 2108 | 6 acute 2 subacute 3 chronic 3 mixed (2–172m post stroke) 8 not specified
de Kroon 2005^113^ | Electrical stimulation | 12 RCT 2 CCT 2 MBD 3 CS | 578 | 4 acute 2 subacute 10 chronic 3 mixed acuity
Dumoulin 2005^88^ | Behavioural therapies in treating urinary incontinence | 4 RCT 1 PR 3 Guidelines | 185 | chronic
Hakkennes 2005^92^ | Constraint-induced movement | 14 RCT 4 SR | 292 | 4 acute 3 subacute 1 subacute/chronic 6 chronic
Henderson 2007^93^ | Virtual reality for upper limb motor recovery | 2 RCT 1 CR 3 PreP | 96 | 3 acute 3 chronic
Larsen 2006^86^ | Early home supported discharge | 8 RCT | 2216 | acute
Lynton 2007^87^ | Yoga | 3 CR | 3 | chronic
Pang 2006^94^ | Aerobic exercise | 7 RCT 2 CCT | 585 | 4 acute 1 subacute 3 chronic 1 mixed acuity
Prange 2006^114^ | Robot-aided therapy (robotic devices on hemiparetic arm function) | 1 RCT 1 CCT 6 BA | 178 | 1 subacute 7 chronic
Riggs 2007^115^ | Visual deficit interventions | 11 RCT 3 CCT 15 CS | 371 | 10 acute 3 subacute 4 acute/subacute 3 chronic 7 mixed 2 not reported
Robbins 2006^116^ | Functional and transcutaneous electric stimulation | 4 CCT 4 BA/CO | 161 | chronic
Seenan 2007^97^ | Organized inpatient (stroke unit) care | 11 CRS 6 BA 3 PR 1 QRCT 3 CaCo | 125,453 | mixed
Stewart 2006^117^ | Bilateral movement training | 11 RCT | 171 | subacute and chronic
Urton 2007^89^ | Treatment interventions (training) for upper extremity hemiparesis | 8 RCT 3 QE | 269 | 1 acute 1 subacute 1 acute/subacute 7 chronic 1 mixed
van Dijk 2005^96^ | Augmented feedback on motor function | 26 RCT 1 NR | 937 | 8 acute 13 chronic 3 subacute 1 mixed 1 not reported
van Peppen 2006^95^ | Visual feedback therapy on postural control | 6 RCT 2 CCT | 214 | acute and subacute (< 20 weeks)

Abbreviations: BA=Before After study, CaCo=Case control study, CCT=Controlled clinical trial; CO=Crossover trials; CR=Case report; CRS=Cross sectional study; CS=Case series; m=months; EMG=electromyography; MBD=Multiple baseline design; NA=not applicable; NR=not reported; OS=Observational study; PR=Prospective study; PreP=Pre-post study; QRCT=quasi-randomized clinical trial; QE=quasi-experimental study; RCT=randomized controlled trial; SR=Systematic review; t=time

Methodologic quality of the systematic reviews. Appendix F details the criteria used to evaluate the methodological qualities of the systematic reviews; the methodological criteria is based on the Oxman and Guyatt scale9,10 scored using an adapted method.11 Table 3 details the scores for the eligible systematic reviews. The majority of systematic reviews published from 2005 forward, were generally well conducted, with only 22 percent (n = 8) of the reviews scoring below 14 out of 18 on our quality assessment checklist. The Cochrane reviews scored highest (range from 16 to 17); Cochrane reviews standardize their reporting and do not have a limit with regards to length of reporting which allows for greater detailing of methods. However, none of the Cochrane reviews met the highest scoring grade (2/2) for question 4 of the Oxman and Guyatt criteria which specified that the reviewers were blinded to identifying features of eligible studies, and assessors were blinded to study outcomes during the selection process. Two Cochrane reviews14,85 were scored lower with regards to detailing their search strategy sufficiently for duplication.

Table 3 Summary of quality assessment using the Oxman and Guyatt9,10 criteria for systematic reviews

Author (Year) | Q1 | Q2 | Q3 | Q4 | Q5 | Q6 | Q7 | Q8 | Q9 | Overall score (max 18)
Cochrane Reviews
Ada 2005^99^ | 2 | 2 | 2 | 1 | 2 | 2^**p^ | 2 | 2 | 2 | 17
Bennett 2005^100^ | 2 | 2 | 2 | 1 | 2 | 2^**^ | 2 | 2 | 2 | 17
Bowen 2007^101^ | 2 | 2 | 2 | 1 | 1 | 2 | 2 | 2 | 2 | 16
Brady 2006^13^ | 2 | 2 | 2 | 1 | 2 | 2^**^ | 2 | 2 | 2 | 17
Discharge Trialists 2005^85^ | 1 | 2 | 2 | 1 | 2 | 2 | 2 | 2 | 2 | 16
French 2007^12^ | 2 | 2 | 2 | 1 | 2 | 2 | 2 | 2 | 2 | 17
Legg 2006^102^ | 2 | 2 | 2 | 1 | 2 | 2 | 2 | 2 | 2 | 17
Mehrholz 2007^103^ | 2 | 2 | 2 | 1 | 2 | 2^**p^ | 2 | 2 | 2 | 17
Moseley 2005^104^ | 2 | 2 | 2 | 1 | 2 | 2^**p^ | 2 | 2 | 2 | 17
Nair 2007^105^ | 2 | 2 | 2 | 1 | 2 | 2 | 2 | 2 | 2 | 17
Pollock 2007^15^ | 2 | 2 | 2 | 1 | 2 | 2 | 2 | 2 | 2 | 17
Pomeroy 2006^98^ | 2 | 2 | 2 | 1 | 2 | 2 | 2 | 2 | 2 | 17
StrokeTrialists 2007^14^ | 1 | 2 | 2 | 1 | 2 | 2 | 2 | 2 | 2 | 16
Thomas 2008^106^ | 2 | 2 | 2 | 1 | 2 | 2^**^ | 2 | 2 | 2 | 17
West 2005^90^ | 2 | 2 | 2 | 1 | 2 | 2 | 2 | 2 | 2 | 17
Woodford 2007^107^ | 2 | 2 | 2 | 1 | 2 | 2 | 2 | 2 | 2 | 17
Wu 2006^108^ | 2 | 2 | 2 | 1 | 2 | 2 | 2 | 2 | 2 | 17
Zhang 2005^109^ | 2 | 2 | 2 | 1 | 2 | 2 | 2 | 2 | 2 | 17
Non-Cochrane Reviews
Ada 2006^91^ | 2 | 2 | 2 | 1 | 2 | 2^**p^ | 2 | 2 | 2 | 17
Bjorklund 2006^110^ | 2 | 2 | 2 | 1 | 1 | 0 | 2 | 2 | 2 | 14
Bonaiuti 2007^111^ | 2 | 1 | 2 | 0 | 2 | 2 | 1 | 1 | 2 | 13
Braun 2006^16^ | 2 | 2 | 2 | 1 | 2 | 2^**^ | 2 | 2 | 2 | 17
Carson 2005^112^ | 2 | 2 | 2 | 1 | 2 | 2^**^ | 2 | 2 | 2 | 17
de Kroon 2005^113^ | 2 | 2 | 2 | 0 | 0 | 0 | 2 | 2 | 1 | 11
Dumoulin 2005^88^ | 2 | 2 | 2 | 0 | 2 | 2^**p^ | 0 | 0 | 2 | 12
Hakkennes 2005^92^ | 2 | 2 | 2 | 1 | 2 | 2^**p^ | 2 | 2 | 2 | 17
Henderson 2007^93^ | 1 | 2 | 2 | 0 | 2 | 2^**p^ | 2 | 2 | 2 | 15
Larsen 2006^86^ | 1 | 0 | 0 | 0 | 0 | 0 | 1 | 1 | 1 | 4
Lynton 2007^87^ | 2 | 2 | 1 | 0 | 0 | 0 | 1 | 0 | 2 | 8
Pang 2006^94^ | 2 | 2 | 2 | 0 | 2 | 2^**p^ | 2 | 2 | 2 | 16
Prange 2006^114^ | 2 | 2 | 2 | 1 | 2 | 2^**^ | 2 | 2 | 2 | 17
Riggs 2007^115^ | 1 | 2 | 2 | 0 | 2 | 1 | 0 | 0 | 2 | 10
Robbins 2006^116^ | 2 | 2 | 2 | 1 | 2 | 2^**^ | 2 | 2 | 2 | 17
Seenan 2007^97^ | 1 | 2 | 2 | 1 | 0 | 0 | 2 | 2 | 2 | 11
Stewart 2006^117^ | 2 | 2 | 2 | 1 | 2 | 2^**^ | 2 | 2 | 2 | 17
Urton 2007^89^ | 2 | 1 | 2 | 1 | 2 | 2^**^ | 0 | 0 | 2 | 12
van Dijk 2005^96^ | 2 | 2 | 2 | 1 | 2 | 2^**p^ | 2 | 2 | 2 | 17
van Peppen 2006^95^ | 2 | 1 | 2 | 1 | 2 | 2^**p^ | 2 | 2 | 2 | 16

** Used a published checklist for quality assessment;

**p used PEDro

For the non-Cochrane reviews, 10 systematic reviews scored lower than 14 (out a maximum score of 18). One review86 combined a systematic review and an economic analysis and had the lowest score of four. The remaining lower composite scores varied from 8^87^ to 12,^88,89^ reflecting primarily problems with bias during the selection process and reporting of rationale and approaches to synthesizing studies. As was the case with the Cochrane reviews, none of the non-Cochrane reviews scored full marks (2/2) for question 4 regarding blinding.

Methodological quality of studies within the systematic reviews. There was great variation in the ways that methodological quality of primary trials was evaluated within the eligible systematic reviews (Table 4). One Cochrane review90 had good methodology but found no eligible articles and thus was excluded from further calculations, leaving 17/18 reviews to be reviewed. All the Cochrane reviews explicitly stated the methodological criteria for evaluating quality of included studies; however, only 6 (33 percent) of these reviews used standardized checklists (see Table 3). The majority of non-Cochrane reviews used standardized checklists or evidence grading systems (n = 13, 65 percent). The PEDro quality assessment scale was used in 6 (46 percent) of these reviews88,91–95 and one review,96 though it did not label the criteria as PEDro, used the first nine criteria of the PEDro scale. Several reviews87,97 evaluated non-comparative studies alone and did not employ any form of methodological evaluation.

Table 4 Comparison of quality elements of individual studies with the systematic reviews

Author (Year) | Mean Score/Number of Items [Range] | Randomization Reported and Described | Allocation Concealment | Baseline Comparability of Groups | Patients Blinded | Healthcare Provider Blinded | Data Collector Blinded | Outcome Assessor Blinded | Dropouts and Withdrawals/ITT | Reporting Adverse Events | Potential for Contamination or Cointervention
Cochrane Reviews
Ada, L (2005)99 | PEDro 5.25/8 [2–8] | 2/4 | 2/4 | 2/4 | NT | NT | 3/4 | 3/4 | 2/4 ITT | 2/4 | NT
Bennett, M (2005)100 | Schulzcriteria NR | 1/3 | 1/3 | NT | 3/3 | 1/3 | 2/3 | 1/3 | 2/3 | 2/3 | NT
Bowen, A (2007)101 | NR | 8/12 | 8/12 | NT | NT | NT | NT | 7/12 | NT | NT | NT
Brady, M (2006)13 | NHSCRD NR | 1/1 | 1/1 | 1/1 | NT | NT | NT | 1/1 | NT | NT | NT
Discharge Trialists (2005)85 | NR | 9/11 | 9/11 | NT | NT | NT | NT | 9/11 | 9/11 | NT | NT
French, B (2007)12 | NR | 13/14 | 8/14 | NT | 1/14 | NT | NT | 11/14 | 12/14 | 4/14 | 4/14
Legg, L (2006)102 | NR | 8/9 | 8/9 | NT | NT | NT | NT | 8/9 | 4/9 ITT | 4/9 | NT
Mehrholz, J (2007)103 | PEDro 7/8 [6–8] | 7/8 | 6/8 | 6/8 | 0/8 | 0/8 | NA | 3/8 | 5/8 ITT | 4/8 | NT
Moseley, A (2005)104 | PEDro 6/8 [4–8] | 12/15 | 9/15 | 12/15 | 0/15 | 0/15 | NA | 11/15 | 3/15 ITT | 13/15 | NT
Nair, R (2007)105 | NR | 0/2 | 0/2 | 2/2 | NT | NT | 0/2 | 0/2 | NT | NT | NT
Pollock, A (2006)15 | NR | 19/21 | 16/21 | NT | 3/21 | 0/21 | 13/21 | NT | 18/21 | NT | 14/21
Pomeroy, VM (2006)98 | NR | 5/24 | 5/24 | 24/24 | 5/24 | 2/24 | NT | 11/24 | 14/24 ITT | 8/24 | 4/24
StrokeTrialists’ (2007)14 | NR | 16/31 | 17/31 | NT | NT | NT | NT | 10/31 | 7/31 | 22/31 | 24/31
Thomas, L (2008)106 | NR | 12/12 | 3/12 | NT | 1/12 | 1/12 | NT | NT | 4/12ITT | NT | NT
West, C (2005)90 | NR | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA
Woodford, H (2007)107 | NR | 1/13 | 1/13 | NT | NT | NT | NT | 13/13 | 2/13 | 0/13 | NT
Wu, H (2006)108 | NR | 0/5 | 0/5 | NT | 1/5 | NT | NT | NT | 0/5 | 0/5 | NT
Zhang, S (2005)109 | NR | 8/14 | 5/14 | NT | 3/14 | NT | NT | 6/14 | 4/14 ITT | 9/14 | NT
Non-Cochrane Reviews
Ada, L (2006)91 | PEDro 4.7/8 [2–8] | 20/21 | 8/21 | 2/5 | 0/21 | 0/21 | NT | 8/21 | 3/21 ITT | NT | NT
Bjorklund, A (2006)110 | NR | 6/11 | NT | NT | NT | NT | NT | NT | NT | NT | NT
Bonaiuti, D (2007)111 | Van Tulder criteria [5–10]/19 | 9/9 | NR | NT | 0/9 | 0/9 | NR | NR | 1/9 ITT | NR | NT
Braun, S (2006)16 | AMCL 5.1/11 [2.5–7] | 4/10 | 3/10 | 2/10 | 1/10 | 1/10 | 3/10 | NT | 0/10 | NT | 4/5
Carson, S (2005)112 | NR | 0/22 | 1/22 | NT | 2/22 | 0/22 | NT | 1/22 | 1/22 ITT | 12/22 | NT
de Kroon, J (2005)113 | NR | 12/19 | NT | 7/19 | NT | NT | NT | NT | NT | NT | NT
Dumoulin, C (2005)88 | PEDro 5.5/10 [5–6] | 4/8 | NT | NT | NT | NT | NT | NT | NT | NT | NT
Hakkennes, S (2005)92 | PEDro 5/10 [3–7] | 13/14 | 2/14 | 10/14 | 0/14 | 0/14 | NT | 10/14 | 4/14 ITT | 2/14 | NT
Henderson, A (2007)93 | PEDro 5.5/10 [3–8] | 1/6 | 1/6 | 2/6 | 0/6 | 0/6 | NT | 1/6 | NT | NT | NT
Larsen, T (2006)86 | NR | NR | NR | 7/7 | NR | NR | NR | NR | 7/7 | 7/7 | NT
Lynton, H (2007)87 | NR | NA | NA | NT | NA | NA | NA | NA | NA | NA | NA
Pang, M (2006)94 | PEDro 6.1/10 [4–8] | 7/9 | 3/9 | 7/9 | 0/9 | 0/9 | NT | 5/9 | 4/9 ITT | 2/9 | NT
Prange, M (2006)114 | Van Tulder Scale 12.75/19 [8–16] | NR | NR | NT | NR | NR | NR | NR | NR | 0/8 | NR
Riggs, R (2007)115 | Class evidence NR | NT | NT | NT | NT | NT | NT | NT | NT | NT | NT
Robbins, S (2006)116 | Downs and Black checklist 15/32 [13–17] | 2/8 | NT | 0/8 | 0/8 | 0/8 | 0/8 | 0/8 | NT | NT | NT
Seenan, P (2007)97 | NR | NT | NT | NT | NT | NT | NT | NT | NT | NT | NT
Stewart, K (2006)117 | Based on Jadad criteria | 9/11 | NT | NT | 9/11 | 0/11 | 0/11 | 0/11 | 3/11 | NT | NT
Urton, M (2007)89 | Sacketts levels [I–V] | 8/11 | NT | NT | NT | NT | NT | 5/11 | 8/11 ITT | NT | NT
van Dijk, H (2005)96 | PEDro 4.5/9 [3–7] | NT | 3/26 | 20/26 | 4/26 | 0/26 | NA | 15/26 | 0/26 ITT | NT | NT
van Peppen, R (2006)95 | PEDro 4/10 [3–6] | 0/8 | 0/8 | NT | 0/8 | 0/8 | 1/8 | 1/8 | 0/8 | NT | NT

Abbreviations: AMCL=Amsterdam-Maastricht Consensus List for quality Assessment; ITT=intention to treat; NR=not reported; NT=Not tested; NA=Not applicable; NHSCRD=National Health Service Centre for Review and Dissemination

There were some methodological quality domains that were not sufficiently evaluated or reported. Figure 15 shows the percent of studies that did not evaluate the criteria of interest. In particular, the potential for contamination, or cointervention was only reported well in 4 Cochrane reviews12,14,15,98 and one non-Cochrane review.16 Similarly, comparing baseline characteristics of the treatment and comparator groups was not evaluated in 12 Cochrane and 11 non-Cochrane reviews reflecting little differences between the two groups of reviews in this domain.

Figure 15 Methodological quality of the systematic reviews

Figure 15. Methodological quality of the systematic reviews

There were some differences between the Cochrane and non-Cochrane reviews. Figure 15 shows that all of the Cochrane reviews reported randomization or allocation concealment (West90 was not included in analysis). Six Cochrane reviews (35 percent) did not evaluate the potential for adverse events compared to 13 (58 percent) of the non-Cochrane reviews. With regards to blinding, many trials evaluated within the systematic reviews indicated that it was impossible to blind the therapist or patient to the treatment and therefore did not evaluate patient or provider blinding. However, the Cochrane reviews tended to be less likely to evaluate this specifically. Both Cochrane and non-Cochrane reviews did not report the status of the data collector. However, they did assess the blinding status of the outcomes assessor (albeit the non-Cochrane reviews evaluated this less frequently).

When methodological criteria were evaluated, Table 4 shows the number of studies within each review that achieved the criteria of interest. In general, within each criteria, the proportions of studies achieving the criteria was wide ranging and likely varied as a function of the stroke rehabilitation intervention. For example, there were examples of reviews where a high proportion of the studies were randomized correctly12 as well as a high proportion of studies that were not.16 The degree to which the stroke rehabilitation intervention influenced this is not known.

### Reporting of Other Study Factors

There are a number of relevant study factors that should have been detailed in the evidence tables within the systematic reviews. Albeit, the degree of information summarized is dependent on the degree it was reported in the original studies. In general, the patient and provider characteristics were better described within the Cochrane reviews than the non-Cochrane reviews (again reflecting the advantage of standardized reporting). The majority of reviews reported sufficient characteristics of the interventions and comparator but less about the “dose” of the therapy to the patients. Similarly, the majority of reviews did not specify the details of the inclusion and exclusion criteria within the studies, or any details of concomitant treatments.

### Summary of Findings from Review of Reviews of Stroke Rehabilitation Interventions

With respect to the review of reviews, there were several trends and methodological points to consider and these include:

1. Most systematic reviews restricted studies to the intervention of interest, and by the type of stroke acuity. Few reviews restricted eligible studies to specific outcomes or to a specific provider of treatment.
2. The Cochrane reviews evaluated predominately randomized trials and the non-Cochrane reviews included all types of designs.
3. Most of the systematic reviews scored relatively high on quality criteria; those that had lower quality scores were non-Cochrane reviews and included multiple design types.
4. Most systematic reviews evaluated methodological aspects of the eligible studies with standardized checklist or criteria. The majority of reviews evaluated randomization, blinding, and withdrawals/dropouts. Fewer reviews evaluated baseline comparability, evaluation of adverse events, and cointervention or contamination.
5. Many reviews indicated that blinding of the patient and the provider was not possible with the stroke rehabilitation intervention and as such the reviews did not evaluate eligible studies for this criterion.

## Systematic Reviews of Outcomes in Stroke Patients

### Characteristics of the Reviews

Three systematic reviews3,4,6 evaluating outcomes within stroke populations were identified through the literature search. Two additional systematic reviews5,17 were identified from searching the references lists of these reviews. One of these reviews,5 published in 1998, was added for two reasons, namely the historical value and because this review had a broader scope in the studies it reviewed relative to the other subsequent systematic reviews. Table 5 details the search parameters, search and eligibility criteria, results, and recommendations within these four systematic reviews of outcomes used in stroke patients.

Table 5 Summary of characteristics and findings of reviews evaluating outcomes in stroke patients

Systematic Review | Purpose Search Eligibility Criteria | Outcomes Classification Framework | Results | Recommendations
Roberts 1998^5^ | Purpose: To assess the appropriateness of outcomes used to measure acute stroke trials in terms of types of outcomes, whether these were assessed blindly, their validity and reliability, and the method of analysis Search: Root to 1996 Cochrane Stroke Trial Registry MEDLINE^®^ Study Eligibility: English only RCT Acute stroke (rehab commenced within 30 days of stroke) | Included: Clinical outcomes Excluded: Non-clinical outcomes (for example biochemical outcomes) Framework: Based on 1980 ICF classification (impairment, disability, handicap) | 174 trials were eligible Most studies did not specify primary and secondary outcomes Most studies used impairment measures (76%) [disability 42% and handicap 2%] The percent of studies using valid and reliable outcomes were as follows: Impairment (35%) Disability (76%) Handicap (25%) For those studies using measures of disability, only 70% used valid and reliable measures; for studies evaluating handicap, only 25% used valid and reliable measures | 1. Measure both impairment and disability (the latter being most meaningful to patients); 2. Use measures that are shown to be valid and reliable.; 3. Assessment of outcomes should be blinded; 4. Appropriate statistics (and methods of categorizing) should be used
Duncan 2000^3^ | Purpose:; 1. To evaluate the use and timing of outcome measures in drug trials; 2. How the use of outcomes is complicated by the natural history of stroke; 3. Make recommendations on how to choose measures for drug trials; Search: 1980 forward (end date not specified) English only Cochrane Stroke Trial Registry MEDLINE^®^ Reference Lists Study Eligibility: Phase II and Phase III RCT of pharmacological interventions in the acute phase of stroke | Included: No restrictions Excluded: Not specified Framework: Based on 1980 ICF model used by Roberts 1998^5^ | 51 studies were eligible 29 of these specifically defined the measure and time frames The majority of instruments selected were reliable and valid Time point for evaluation varied but 3 months was the most frequently selected timepoint The cutpoints indicating “improvement” or favorable response was also variable (usually chosen for arbitrary reasons) often for the same outcomes. This is a reflection of the lack of consistency in defining clinically meaningful changes | 1. Primary outcomes should be at the level of activities (to include instrumental ADL and advanced mobility; 2. Impairment outcomes should be included to assess whether the drug has affected neurological recovery; 3. Assessment of individual emotion should be considered; 4. All outcome measures should have established psychometric properties (reliable, valid, sensitive to change); 5. Definition of recovery should not be dichotomized but rather should assess shifts in disability by use of non-parametric statistics; 6. Primary outcomes should be assessed at 6 months (especially in severe stroke) to take into account spontaneous recovery (that can occur at 5 or 6 months); 7. Data collection should include baseline characteristics that confound outcomes; 8. Stroke specific outcomes that capture domains within the ICF should be used
Golomb 2001^17^ | Purpose: To evaluate HRQoL measures for use with stroke patients with respect to a) coverage of important HRQoL domains that may be related to stroke, b) have administration characteristics suitable for stroke, and c) have undergone reliability and validity assessment in stroke patients Search: 1985 to 1998 English only MEDLINE^®^ Excerpta Medica PsychINFO^®^ Mental Health Abstracts Study Eligibility: No study design restriction provided individual level data on stroke | Included: No restrictions Excluded: Not specified Framework: Not specified | Identified 32 different outcome measures; - physical functioning (n=8); - emotional well-being (n=14); - generic multiple domain (n=10); - stroke specific (n=1); Many measures had not been assessed or validated in stroke specific populations Almost all measures have extremely limited information on responsiveness No existing measure covers all domains of HRQoL that may be relevant for stroke patients | 1. Recommend the development of stroke specific measures of HRQoL; 2. Future work should validate measures currently used within the stroke population
Geyh 2007^4^ | Purpose:; 1. To identify current generic and condition-specific HRQoL measures applied in stroke patients; 2. to examine the contents of the measures based on linkages to the ICF; 3. To compare contents of the generic and stroke specific HRQoL measures; Search: 1990 to 2004 English only MEDLINE^®^ EMBASE^®^ PsychINfo^®^ Study Eligibility: No study design restriction (except case series and economic evaluations) and psychometric studies of relevant outcomes All phases of stroke recovery | Included: No restrictions specified Selected the most frequent generic and five most frequent stroke specific HRQoL measures for content comparison Framework: ICF classification | 71 studies were eligible and within these 23 different HRQoL measures were used Selected 7 stroke specific instruments (SIS, SSQoL, SAQoL, QLI-SV, SA-SIP30, BOSS, HS-Quale) and six generic instruments (SF36, RNL, SIP, EQ-5D, LHS, NHP) for content analysis 979 ICF concepts were identified within the 13 instruments evaluated Stroke specific outcomes more often address mental functions, while the generic instruments often include environmental factors (i.e. assistive devices, or support) Generic instruments tend to address pain, independence and family relations more often reflecting the burden of the disease; stroke specific measures tend to address walking, speaking, energy, etc, reflecting the direct impact of the stroke on the individual’s daily life For 13 outcomes evaluated the content density, content diversity and bandwidth of content coverage has been established | 1. The purpose, patients and setting, and resources should be considered when selecting a HRQoL outcome measure in stroke patients; 2. Suitability of a HRQoL outcome measure must consider the psychometric properties and feasibility of administration; 3. A core ICF set has been established for Stroke (developed with the WHO) and can be used to determine what should be measured in studies on stroke patients. This core set can be compared with the content analysis on any outcome being considered
Mudge 2007^6^ | Purpose:; 1. To determine the range of outcomes currently used in stroke that include an assessment of an aspect of walking ability; 2. To estimate the researcher acceptance of different measures by calculating the frequency of use in the published literature over the last 15 years; 3. To determine the breadth of content of walking assessment with respect to the ICF subclassification; Search: 1990 to 2005 MEDLINE^®^ CINAHL^®^ EMBASE^®^ PsychINFO^®^ Study Eligibility: No study design restriction (including outcome measure development studies) except case series. All phases of stroke recovery | Included: To include at least one component of walking ability according to ICF (not focused on measuring mobility) The outcome was to have published psychometric properties Excluded: Outcome had to have a version in English Framework: ICF classification | 357 studies were eligible (65 RCT, 65 prospective cohorts, 6 retrospective, 109 psychometric properties of developmental studies, and 112 experimental studies) identified 61 different outcomes Included acute, sub-acute and unspecified timeframe stroke populations The most frequently used measures of walking ability, self-paced walking speed, spatiotemporal parameters and fast gait speed, only measure one aspect of walking ability Measures that included greater breadth in capturing walking ability are less frequently used Although researchers tended to select more than one walking ability outcome, mobility tasks related to the community were not well represented in the majority of outcome measures and studies | 1. Measures of walking ability should represent the breadth of walking ability (include activities that also includes more complex walking, such as around obstacles, and on uneven surfaces or in the community); 2. There is a need for researchers and clinicians to define the most useful concepts that should be captured to more accurately reflect the range of walking ability; 3. Further research is required to determine whether the combination of self-report and activity monitor (i.e pedometers, etc.) can minimize some of the limitations of self report questionnaires

Abbreviations: BOSS=Burden of Stroke Scale; EQ-5D=European Quality of Life Instrument; HRQoL=health-related quality of life; HS-Quale=Quality of Life Instrument for Young Hemmorhagic Stroke Patients; ICF=international classification of functioning; LHS=London Handicap Scale; NHP=Nottingham Health Profile; QLI-SV=Quality of Life Index-Stroke Version; RCT=randomized controlled trial; RNL=Reintegration to Normal Living Index; SAQoL=Stroke and Aphasia Quality of Life Scale; SA-SIP30=Stroke Adapted Sickness Impact Profile-30; SF36=Medical Outcomes Study 36-item short form health survey; SIP=Sickness impact profile; SIS=Stroke Impact Scale; SSQoL=Stroke Specific Quality of Life

All reviews evaluated English language publications only (one of these reviews6 had a criterion that all outcomes had to have an English translation). Two reviews3,5 included studies from 1966 to mid to late 1990s; one review17 included studies from 1985 to 1998. The remaining two systematic reviews4,6 included studies from 1990 up to and including 2005.

### Types of Outcomes Evaluated and Findings

All reviews attempted to evaluate the range of outcomes used, the frequency of their use, and the breadth of content (classification within theoretical frameworks) (Table 5). One review3 selected studies that included only acute stroke subjects who were receiving drug therapy. Two reviews4,17 evaluated studies specific to health related quality of life (HRQoL) outcomes, while another review6 evaluated only studies with outcomes pertaining to walking ability. Two reviews3,5 evaluated studies in acute stroke patients, two reviews4,6 stroke patients in all phases of recovery, and one review17 did not specify. A distinction between the reviews published earlier and those published in 2007, is the difference in the theoretical frameworks used to classify the content of the instruments evaluated. The later publications use the current ICF classification (1990)4,6 and the earlier publications an earlier (1980) categorization (including impairment, disability and handicap).3,5,17

The difference in frameworks used to classify the attributes of the outcomes, is also reflected in the types of recommendations elicited from these reviews. All the reviews generally conclude that there are a variety of outcomes used to measure the same attributes of interest. All review authors recommend the selection of outcome measures that have established psychometric properties (reliable, valid, and responsive). In addition, floor and ceiling effects (where scores are extremely high or very low making it difficult to detect changes over time), as well as practical administration issues, should be considered when selecting outcomes.4 In general, the reviews appear to suggest that no measure is able to capture the breadth of the domains that they are attempting to capture and as such the recommendation is to include other measures that capture other domains (e.g., activity level and not just impairment).5 Similarly, there is the recommendation to use more than one outcome measure in order to capture all attributes within the domain of interest (for example walking ability); however, there was some acknowledgement that consensus has not yet been achieved to define the concepts that should be captured to most accurately reflect the range of some aspects of function (such as walking).6

Only one review3 evaluated the time-points selected for evaluating final outcomes in stroke patients (for example, 3 or 6 months post-treatment). In this review based on 51 studies, evaluating the use of drugs in acute stroke, the majority of studies evaluated patients at 3 months and none exceeded 1 year. Two reviews3,5 described the statistical methods used to evaluate rehabilitation effects; the findings of both reviews would suggest that there is a need to establish the degree of change that is considered to be clinical significant and that there appropriate statistical analyses be undertaken within future studies.

### Summary of Systematic Reviews of Outcome Measures in Stroke

The systematic reviews of the outcome measures used in studies with stroke patients would indicate the following:

1. A variety of outcomes have been used to measure the same attributes of interest within studies of rehabilitation interventions in persons with stroke.
2. Currently, no single outcome measure captures all relevant dimensions of important attributes of interest to stroke patients and clinicians. This implies that measures that capture these multiple domains be included. Whether a single measure captures more than a one dimension (for example body function and activity and participation) or whether several measures are used to capture the dimension is less critical than ensuring that all domains are captured.
3. All dimensions of an outcome of interest should be evaluated. For example, if walking ability is of interest, then walking in all life conditions (including walking within the home, outside the home in uneven ground, and in changing weather conditions) should be evaluated.
4. Future studies evaluating rehabilitation therapies in stroke patients should select outcome measures that have established psychometric properties in stroke (reliable, valid, and responsive)
5. Floor and ceiling effects, as well as practical administration issues, should be considered when selecting outcomes.
6. The timing of outcome measurement should be justified, with some consideration of the natural history of stroke recovery.