# Methods

## Literature Search Strategy

There were two different strategies used to identify publications that evaluated rehabilitation therapies for stroke patients. In the first strategy, known as purposive sampling, the literature search was designed to identify articles that evaluated therapies in any one of six possible outcome domains: cognition, ambulation, quality of life (QoL), activities of daily living (ADLs), communication, and dysphagia. The objective was to identify a maximum of 20 articles in each domain. The decision was made to select the 20 most recent publications in each domain to provide the most up-to-date picture of the methodological standards currently employed in stroke rehabilitation research. If fewer than 20 articles were found in a particular domain after conducting the search, then the time scope of the search was not broadened because few comparative studies were likely to exist in that domain.

MEDLINE^®^ and CINAHL^®^ were the primary databases used in the search, although they were supplemented by PsycINFO^®^ in the case of three domains with a clear psychological component (i.e., cognition, communication, dysphagia). For each of the six domains, the literature search was conducted by combining terms for the relevant domain with terms for stroke and rehabilitation. The detailed search strategy is contained in Appendix A.

Tailored search strategies and time scopes for each domain were as follows:

1. Cognition was searched in MEDLINE^®^, CINAHL^®^, and PsycINFO^®^ between January 1, 2000 and January 21, 2008;
2. Communication (including speech) was searched in MEDLINE^®^, CINAHL^®^, and PsycINFO^®^ between January 1, 2000 and January 22, 2008;
3. Dysphagia was searched in MEDLINE^®^, CINAHL^®^, and PsycINFO^®^ between January 1, 2003 and January 18, 2008; and
4. Ambulation, QoL, and ADLs were searched in MEDLINE^®^ and CINAHL^®^ between January 1, 2003 and January 15, 2008.

In the second strategy, a broader search was undertaken to identify systematic reviews on the general topic of stroke rehabilitation. MEDLINE^®^, CINAHL^®^, and the Cochrane Database of Systematic Reviews (CDSR) were searched between January 1, 2000 and January 16, 2008. The search terms for the review of reviews were a combination of stroke, rehabilitation, and outcomes, as well as subject terms for systematic review.

Inclusion/exclusion criteria. A purposive sampling approach was taken to select studies for this technology assessment. To be included in the assessment, the main focus of an article had to be stroke (or cerebrovascular accident) in adults. The study design had to contain a distinct comparison group (e.g., randomized controlled trial, controlled clinical trial, cohort or case control study). Studies involving persons who acted as their own controls (e.g., single subject research design (SSRDs)) were excluded because they do not involve distinct comparison groups (see Chapter 1). Included studies could contain any type of rehabilitation therapy whose effect was evaluated using any outcome in the domains of cognition, ambulation, QoL, ADLs, communication, or dysphagia. In the case of drugs used as rehabilitation therapies, included studies had to contain a drug that was employed to treat cognitive impairment. Other types of rehabilitation drug studies were excluded.

Searches were limited to English-language articles involving human subjects. Editorials, letters to the editor, comments, and studies without a comparison group (e.g., case reports, case series) were excluded from this technology assessment. A further exclusion was applied to studies that focused on primary or secondary stroke prevention.

These same criteria were applied to include systematic reviews in the review of reviews, with some exceptions. First, the focus of a review could be on any rehabilitation therapy administered to a stroke patient, regardless of outcome domain. Second, the article had to be a systematic review of the literature. Narrative reviews or opinion pieces summarizing states of knowledge were excluded from the assessment. Third, there were a large number of reviews that focused on the use of drugs in the immediate acute phase of stroke; there were also a number of reviews that evaluated the use of drugs for prevention of future stroke (primary or secondary) or prevention of thrombosis following stroke. In these reviews, the use of drugs was not considered to be for “rehabilitation”, so the reviews were excluded. Reviews in which drugs were used to treat post-stroke depression or emotionalism were also excluded. Similarly, reviews about the treatment of spasticity and pain following stroke were excluded at the request of CMS. Finally due to the large number of systematic reviews, we limited our evaluation to those published from 2005 onward.

### Data Screening and Abstraction

Data screening. The search results were imported into Reference Manager^®^ v10 (Thomson ResearchSoft; Carlsbad, CA). At level one of screening (title and abstract screening), two independent reviewers applied the inclusion/exclusion criteria to all articles retrieved in the literature search. This was done for both the purposive sampling and review of reviews. Screening was done separately for each of the six outcome domains. Lists of articles that were selected for inclusion by each reviewer were compiled on a domain-by-domain basis. Within each domain, the first 20 matching articles from both reviewers’ lists, in chronological order of publication (most to least recent), were included in the assessment. For the review of reviews, screening yielded a large number of eligible systematic reviews (n = 126); given that such a large number was not feasible, we limited the eligible systematic reviews to the period from 2005 to the present.

Data abstraction. Articles selected for inclusion at level one advanced to level two of screening. This was the data abstraction phase, which was also conducted by two independent reviewers. Disagreements were resolved by consensus. Abstracted data were entered into standardized evidence tables, which were developed iteratively by the McMaster University Evidence-based Practice Center (MU-EPC) team to address the specific information needs of Centers for Medicare and Medicaid Services (CMS). Elements for extraction from the primary studies included characteristics of the study, population, intervention, comparator, outcomes, comparator treatment, and results. Summary information across studies with respect to the frequency of outcomes was also extracted. Elements for extraction in the review of reviews included eligibility criteria for the systematic review (design, outcomes, comparison, population), details of the search strategy, methods of assessing individual study quality, and the main findings. Individual study data for key methodological attributes (randomization, blinding, withdrawals) were also extracted and summarized across systematic reviews.

Studies or reviews could be excluded at each level of screening if they were found to not meet the inclusion/exclusion criteria.

Quality assessment. For the primary studies, we evaluated methodological characteristics, and summarized them in tabular form. We also summarized two studies per outcome domain in the text: one study that exemplified good methodological quality and one study that exemplified less than high methodological quality. For the review of reviews, we developed a standardized checklist for quality focusing on four main aspects of internal validity, namely randomization (allocation concealment), blinding, withdrawals, and control of baseline confounders (for cohort studies). For the review of reviews, we utilized a standardized quality assessment checklist9,10 with a modified scoring system11 whereby the maximum score was 18.

### Technical Experts

The MU-EPC enlisted two content advisors to provide advice on data abstraction and the interpretation and significance of results. Communication with these advisors was undertaken on an ‘as needed’ basis to provide intellectual input and discussion of findings.

The advisors included Drs. Laurie Wishart and Maria Huijbregts. Dr. Wishart is the Assistant Dean of the Physiotherapy program at McMaster University’s School of Rehabilitation Science. Her research interests include the development of effective rehabilitation interventions for older adults and individuals post-stroke. Dr. Huijbregts is the Director of Clinical Evaluation at Baycrest, an academic health sciences centre on aging that is affiliated with the University of Toronto. She is also an Associate Scientist at the Kunin Lunenfeld Applied Research Unit, which is part of Baycrest. Dr. Huijbregts conducts research into self-management approaches to programming for stroke survivors in the community.