# Introduction

The Coverage and Analysis Group at the Centers for Medicare and Medicaid Services (CMS) requested this report from The Technology Assessment Program (TAP) at the Agency for Healthcare Research and Quality (AHRQ). AHRQ assigned this report to the following Evidence-based Practice Center: McMaster University (MU-EPC) (Contract Number: HHSA 290-2007-10060-I). The assessment served as background information for a CMS Evidence Forum and the Medicare Evidence Development and Coverage Advisory Committee (MedCAC) meeting held on May 21, 2008. The primary goal of the assessment was to describe key methodological issues in studies designed to assess rehabilitation therapies administered to patients with stroke. Researchers in stroke rehabilitation may wish to use this assessment as a guide to help avoid pitfalls in the design and conduct of future studies in this area.

## Definition and Epidemiology of Stroke

According to the World Health Organization, a stroke or cerebral vascular accident (CVA) is an acute onset of neurological dysfunction due to an abnormality in cerebral circulation. The resultant signs and symptoms of the abnormality must last for more than 24 hours and there must be corresponding involvement in focal areas of the brain.21 Of all strokes, 87 percent are ischemic, 10 percent are intracerebral hemorrhage, and 3 percent are subarachnoid hemorrhage.22

Strokes are the third leading cause of death in the United States, behind heart disease and cancer. Moreover, strokes are the second most common cause of disability.23 In 2004, 150,074 people died from stroke related problems and stroke accounted for 1 out of every 16 deaths in the United States.23 Each year, 780,000 people experience a new or recurrent stroke23 and approximately 600,000 of these are incident cases. Of the people who have had a stroke, two-thirds will survive, but half will be left with permanent disabilities.24 In 2005, 5.8 million American adults were living with the sequela from stroke.23

In the United States, the estimated cost of stroke-related morbidity for 2008 is $65.5 billion.23 In 2003, $3.7 billion was paid to the facilities and providers of care for Medicare recipients who were discharged from short-stay hospitals with a diagnosis of stroke.25 The mean lifetime cost of ischemic stroke in the United States is estimated at $140,048 per person (based on estimates in 1999). This number includes the cost of inpatient care, rehabilitation, and followup management.26

Risk factors for stroke. There are numerous modifiable and non-modifiable risk factors for strokes. Of these, the single greatest modifiable risk factor is hypertension, which at age 50 results in a 4-fold increase in risk of stroke.23,27 The presence of atrial fibrillation also increases the risk of stroke by a factor of four. Physical inactivity, cigarette smoking, and obesity are also significant modifiable risk factors for stroke.27 Non-modifiable risk factors for stroke include a prior stroke, increasing age, race, gender, and family medical history.23,27

### Clinical Consequences of Stroke

The clinical consequences of stroke are variable and influenced by the location of the stroke in the brain and the extent of cell damage. Following a stroke, patients may have complications that span a wide range of body functions. These can include difficulties related to sensory and motor control, vision, cognition (perception [i.e., hemispheric neglect] and spatial orientation), balance (i.e., ambulation), basic life function (i.e., respiration), communication (i.e., speech and aphasia), and behavior (i.e., timid behavior and impulsivity).28 There may also be varying degrees of difficulty with activities of daily living such as bathing, toileting, self care, and cooking. Persons recovering from stroke may also be unable to drive or work.28 All of these complications can adversely affect a patient’s quality of life (QoL). The aim of stroke rehabilitation is to counteract limitations in all areas of patient function, maximize patient ability to be independent and productive, and improve QoL.

The natural history of stroke suggests that functional changes will vary over months and even years, despite the fact that the greatest changes occur within the first 30 days post-stroke.8 The rate of functional change may be influenced by the initial severity of the stroke and potentially by the timing and intensity of rehabilitation.14 Additionally, the recovery and selection of treatments will be influenced by the type of stroke, with ischemic requiring subsequent use of blood anti-coagulants such as low molecular weight heparin. There is no consensus as to how to classify the intervals of recovery following stroke. The definitions of acute, subacute, and chronic stroke are arbitrary and variable. The confusion is furthered by assuming that the location of the rehabilitation (e.g., an acute care or inpatient hospital) is synonymous with the acuity or timepoint relative to the initial stroke trauma. For the purposes of this review, we have defined acute stroke as 1 to 90 days, subacute as 91 to 180 days, and chronic stroke as greater than 180 days.

### Classifying Functional Changes in Patients Undergoing Rehabilitation

At its best, rehabilitation therapy is an enabling process through which physical, sensory, or mental capacities are restored or enabled.29 The International Classification of Functioning, Disability, and Health (ICF)30 is the current framework developed through the World Health Organization to present a consistent terminology for classifying health and health states. It permits comparison of data across countries, health systems, health care disciplines, health services, and time. More importantly, it also provides a common terminology between health professionals, policy makers, and the public (particularly those with disabilities).

The ICF is composed of two main parts: Part 1 describes functioning and disability and Part 2 describes contextual factors (Figure 1). Part 1 is further characterized by two main components, namely physiological functions of the body systems (including psychological) and the anatomical parts of the body (e.g., the limbs, the organs, etc.,). Part 1 also includes activities (the execution of a task or action by an individual) and participation (e.g., involvement in life situations). Part 2 is characterized by two main components that describe external environmental factors (the physical, social, and attitudinal environment in which people are living) and intrinsic personal factors (e.g., genetics or age).

Figure 1 ICF classification30 (Permission to reprint granted by World Health Organization (WHO))

Figure 1. ICF classification30 (Permission to reprint granted by World Health Organization (WHO))

Parts 1 and 2 include positive aspects that describe the health or health related state of an individual. For example, in Part 1 (body functioning and structures), a positive health state is reflected in functional and structural integration, which is classified as functioning. In contrast, a negative aspect reflects impairment (a significant loss or deviation in body function or structure) and a resulting limitation in activity (difficulties in executing a task) or restriction in participation (problems in engaging in life situations). Similarly, for Part 2 (contextual factors), positive environmental factors are classified as facilitators and the corollary are barriers or hindrances; however, it should be noted that positive or negative aspects cannot be ascribed to the personal factors, which is the second component of Part 2 (Figure 1).

The ICF framework provides a common language to characterize the health of a particular group of patients. As such, it defines the specific body structures and functions that result in impairment, activity limitation, and participation restriction. Once a health state is classified, the ICF constructs can be used to identify the areas that certain therapies, intervention categories, or therapists may address.31 These constructs may also be used to identify areas that will not be modifiable in the context of care.32 Similarly, the ICF classification has been used to decompose attributes of outcome measures used to evaluate rehabilitation therapies; as such, the content of these outcomes can be evaluated for deficits or strengths in capturing all aspects of the health state for particular conditions such as stroke.6,33 Decomposition of the most frequently used outcome measures within stroke rehabilitation studies has been used as a basis for consensus on an important core set of functions affected by stroke.20

### Modelling the Process of Functioning and Disability

When characterizing a person’s health state, there is a relationship between Part 1 and Part 2 components. As a classification system, the ICF (Figure 1) does not necessarily model the process of disablement or functioning because this may vary with the health condition. However, the interrelationship between the ICF components can be used to describe the process of disablement or functioning. For example, Figure 2 shows the relationship between Activities and Body Functions and Structures; in addition it suggests that the environmental factors influence Body Functions and Structures via Activities. Using stroke as a health state, we can hypothesize that the lack of adequate mobility technology (such as wheelchairs) will impact a stroke client’s ability to undertake activities, which in turn may affect the Body Function and Structure of leg strength. Although, a core set of functions within the four domains of the ICF framework have been identified and described for stroke clients,20 there is a need to model how these components and domains inter-relate to bring about function or disability. Note that there are a number of models within rehabilitation that attempt to provide theoretical explanations for the disablement process (that is for the pathways and directions that lead to disability or restoration of abilities). The scope of this review does not permit detailing these different models. However, the use of the ICF taxonomy is critical for a common understanding of the components within these disability models.

Figure 2 ICF and process of disablement and function30 (Permission to reprint granted by WHO)

Figure 2. ICF and process of disablement and function 30 (Permission to reprint granted by WHO)

### Methodology of Studies of Stroke Rehabilitation Therapies

The evaluation of the methodology of studies in rehabilitation therapies applied to stroke patients should follow the basic tenets of evidence-based practice (EBP). In short, EBP is the use of the best available evidence in healthcare research to make decisions about patient care.34 The implementation of EBP requires a recognition of the need for evidence, the development of focused and answerable questions about clinical dilemmas, the search for appropriate publications in the medical literature, and the critical appraisal of these publications.35

Methodological evaluation falls under the ‘critical appraisal’ aspect of EBP. The intent is to assess whether studies are designed and executed properly. Poorly designed or executed studies are more likely to produce biased and invalid results. Study design concerns the type of study itself (e.g., randomized controlled trial [RCT], observational study), length of followup (long enough to detect important outcomes), and type of analysis. This forms a portion of what is commonly termed PICOT (Population, Intervention, Comparison, Outcome, Time). PICOT is used to guide the formulation of research questions in EBP. However, all of its components are relevant to study design. The study must include persons sampled from the population in which the therapy will be used. The therapy (intervention) must be clearly described and evaluated in conjunction with a comparison therapy that is an existing alternative treatment for stroke rehabilitation. Study outcomes must also be clearly defined and linked to the objective of the rehabilitation therapy under consideration. For example, the efficacy of a therapy aimed at improving post-stroke cognition should be evaluated using a valid and reliable measure of cognition in stroke patients. Furthermore, the length of followup should be long enough to show improvement in the outcome domain of interest.

The execution of a study is also important. The people who participate in a study should be representative of the population of interest. This involves taking active efforts during the course of the study to minimize dropout and losses to followup. Prior and concurrent treatments should be described to assess whether study participants received or are receiving atypical treatments that could affect their response to rehabilitation therapy. If study participants do not resemble the population of interest, then selection bias may be introduced into the study. This bias leads to over or underestimates of the true association between a set of therapies and the outcome(s) of interest. Once in the study, participants must be evaluated in an objective and identical manner regardless of the intervention received. Participants must also be correctly categorized on outcome, for example stroke patients who recover half of their pre-stroke mobility should be properly categorized as such. Failure in any of the areas pertaining to patients who are already in the study could result in the introduction of information bias, which like selection bias can lead to an over or underestimate of a true effect size.

In practice, it is difficult to distinguish between design and execution issues in the consideration of bias. Biases may arise at any point in the life of a study. A properly executed study is predicated on good design to minimize bias. However, a well-designed study can still produce biased results such as when an unexpectedly large number of participants dropout after receiving one of the therapies under investigation. Another potential example would occur when it is impossible to blind participants and outcome assessors due to visible differences between therapies. These ‘visible differences’ may be prevalent in stroke rehabilitation due to different types or appearances of equipment, as well as to multifactorial treatment regimens that may involve several interventions, multiple therapists, and tailoring to meet individual patient needs. There are also some biases and errors that are context specific to the types of interventions employed or to the equipment used to capture data. For example, studies that use force plates to capture ground reaction forces (to assess changes in ambulation and balance) have particular problems with drift (if they get overheated) and they may also constrain the manner in which a person would normally walk or stand.

Bias is not easily quantifiable. There are few statistical tests to examine whether observed results have occurred due to bias. Nor are there effective means to establish the direction and magnitude of any bias that may be present. Persons who use EBP to assess therapies should examine the methodological strength of the pool of studies under consideration and make a judgment as to the presence and magnitude of any bias. Studies thought to contain a great deal of bias may be given little or no weight in subsequent decisions. Please refer to Rothman and Greenland36 or Silman and Macfarlane37 for a more complete discussion of general biases in clinical studies.

Types of comparison studies. The most useful evidence for or against a new therapy would come from studies that have a comparison group. Such a group would act as a referent and allow decision makers to evaluate the new therapy against an existing yardstick. This contextualizes the efficacy of a new therapy. For example, the new therapy might improve cognition by 50 percent in stroke patients after six months, but is 50 percent a good figure? If improvement is 70 percent for the comparator therapy, then 50 percent may not be an adequate level of efficacy.

Of course, the validity of the comparison depends on the comparator therapy. The comparator should be clinically relevant and clinically routine. That is, the comparator should be an existing, approved therapy in the same class as the new therapy. The comparator should also be utilized according to standard practice norms. For example, if persons with stroke typically have three treatment sessions per week with the comparison therapy, then this same protocol should be followed in the study. The purpose of having a clinically relevant and routine comparator is to prevent situations where the new therapy might look better because the comparator is being implemented incorrectly. The need to have a comparison group rules out the use of case reports or case series to assess medical evidence.

Figure 3 shows a schematic representation of study designs and their potential for bias. The pyramid suggests that higher-level studies are less prone to bias and reflect stronger evidence for the therapies being evaluated. Studies without comparison groups in general are more prone to biases and as such would indicate lower levels of clinical evidence. Each design type, as noted previously has strengths and limitations and their relative merits are considered in the context of the research purposes that are to be addressed.

Figure 3 Schematic showing the strength of evidence and the influence of study design

Figure 3. Schematic showing the strength of evidence and the influence of study design

Studies with comparison groups fall into two general categories: intervention or observational studies.36 An intervention study is one where the investigator controls the exposure (e.g., treatment or risk factor). In healthcare research, intervention studies take the form of RCTs, where participants are randomly allocated to one of two or more treatments. RCTs are considered the gold standard in medical research and EBP because the randomization process (if done properly) will usually ensure that the study subjects assigned to the various treatment groups are similar to one another on all characteristics except the therapy in question.38 This negates the impact of important biases such as confounding, which occurs when one or more extraneous variables are associated with both the interventions under consideration and the outcomes of interest (provided the extraneous variable is not in the causal pathway between the interventions and outcomes). Confounding can reverse the direction of association between two variables, change the magnitude of the association, create an association where none really exists, or eliminate an association that truly exists. Data on variables that are thought to be confounders should be collected at baseline and at all followup points. Examples of potential confounders in stroke are type of cerebrovascular event, comorbid disorders, concomitant treatments, age, and sex.

In contrast to RCTs, observational studies do not involve randomization to treatment. Study subjects are still divided by intervention, but the division is not controlled by the investigator. For example, investigators may access a medicare database and group persons in the database according to the type of therapy they are shown to be receiving. The investigators do not assign the therapy, but rather accept already existing classifications of subjects. The investigators also do not control how the therapy is provided to patients. They must accept the protocols used to deliver therapy to the patients whose data are contained in the database. The two most prominent observational study designs are cohort and case control studies. In cohort studies, subjects are classified according to the intervention they receive and followed up over time, usually until they have an outcome or the study finishes. In case control studies, subjects are classified according to outcome and the investigators determine whether subjects have been ‘exposed’ to some agent or treatment in the past. Exposure assessment in case control studies is ascertained via subject or proxy interviews, or by examining records (e.g., databases, death certificates, hospital charts). Observational studies are ranked lower on the evidentiary scale than RCTs because the lack of randomization leads these designs to be more susceptible to confounding than RCTs. However, observational studies are a useful means of harnessing existing data to study associations before undertaking expensive RCTs.

While RCTs are the gold standard, they are subject to selection and information bias, as are observational studies. Furthermore, RCTs are often used to address questions of efficacy (can an intervention work), not effectiveness (does an intervention work in the real clinical world). Therefore, RCTs often include study subjects who are atypical of the wider population that would receive an intervention in standard medical practice situations.39 This can limit the generalizability of an RCT’s results to a very small segment of the wider population (e.g., good compliers). More information on the various types of study designs is available by consulting Silman and Macfarlane37 or Benson and Hartz.40

In stroke rehabilitation, the customized, multifactorial approach to treatment often makes RCTs an impractical means of assessing a specific therapy.41 RCTs are more suited to situations where a unimodal therapeutic regimen (e.g., one single drug or its comparator) is given to patients. Some stroke researchers have proposed a ‘clinical practice improvement’ (CPI) research method to overcome the problems of using RCTs to evaluate stroke rehabilitation therapies.41 CPI studies are essentially cohort studies designed to address practical questions related to the effectiveness of an intervention, (e.g., does the intervention work in standard clinical settings and for whom does the intervention work best?).

A study design that is sometimes seen in stroke rehabilitation is called a ‘single subject research design’ (SSRD).42 SSRDs have recently been used to evaluate things such as body weight support gait training in the enhancement of post-stroke locomotor recovery.43 In SSRDs, participants serve as their own controls through exposure to both the intervention being evaluated and the comparator. SSRDs do not necessarily involve a sample size of one person. They can include multiple subjects who act as their own controls. Studies wherein subjects are randomized to the order of treatment (intervention followed by comparator or vice versa) are known as ‘crossover trials’. SSRDs in stroke typically do not involve randomization. All subjects are given the comparator treatment (often standard therapy) initially, followed by the intervention, and concluding once again with the comparator. When the comparator is standard treatment, the intervention is usually given as a supplement to the standard treatment. The problem with using such SSRDs in stroke rehabilitation is that patients may improve over time on the standard therapy, so it may be difficult to attribute some or all observed improvements during the intervention phase to the intervention itself. This is known as an ordering effect.44

Phase I and Phase II trials, which typically involve a single group of subjects who all receive the intervention of interest, may occasionally be used to evaluate a stroke rehabilitation therapy. Caution should be exercised in the use of these studies for evaluative purposes in stroke. Phase I studies involve healthy volunteers and are usually conducted in the realm of drug therapy to establish safety, tolerability, toxicity, and dose range. Efficacy is not the primary motivation for undertaking a Phase I study. Phase II studies, which include subjects with the medical condition of interest, may have efficacy as an outcome. However, Phase II studies still lack a comparison group, so this design cannot be used to directly compare the impact of a new intervention with the impact of an existing intervention.

In short, all aspects of the design and execution of a study are relevant to assessing a new rehabilitation therapy for stroke patients. Poorly designed or executed studies raise the specter of invalid results (e.g., biased results).

Characteristics of comparator treatments. As discussed in the section above, a valid comparator is needed in stroke rehabilitation studies. In many studies, the comparator is some kind of standard therapy that is normally given to all stroke patients. Due to the heterogeneity of case presentation in stroke, the standard therapeutic regimen will differ according to individual patients and their disabilities. Another source of difference is the particular treatment philosophy held by rehabilitation professionals. The generic term ‘standard therapy’ may therefore be inadequate to describe the comparator treatment in a research study. Researchers should make an effort to carefully describe what they mean by standard therapy in their studies so that the scientific community can assess the validity of the comparator.

Clinical practice guidelines45–49 for stroke rehabilitation can provide some details of the components of a standard therapy. Authors who employ standard therapies in their research studies should consider using some of these components as descriptors of what they mean by ‘standard therapy’. Of course, rehabilitation therapies are tailored to the needs of specific patients, so it is difficult to create a checklist of components that must be described in every study. At a bare minimum, the authors should report the timing, frequency, and duration of the intervention, the type of person conducting the intervention (e.g., physical therapist), and the nature of the intervention itself (e.g., describe devices used in therapy, describe exercise programs). It would be sufficient to reference well-known, standard devices, tests, etc., without providing lengthy descriptions in the text of a journal article. However, little-known devices or tests (if used as standard treatment) should be explained and referenced. Generic names (e.g., ‘gait test’) should be avoided unless there is no proper name for the device or test.

The guidelines45–49 for stroke rehabilitation focus on the general principles of providing standard therapy, rather than on listing specific treatment approaches to particular problems. This reflects the heterogeneity inherent in current stroke rehabilitation approaches. In general, some guidelines recommend that a rehabilitation assessment should take place within 24 to 48 hours post-stroke. These assessments should be made by patients, patients’ families, and multidisciplinary care teams consisting of physicians, skilled rehabilitation nurses, physical therapists, occupational therapists, kinesiotherapists, speech and language pathologists, psychologists, recreational therapists, social workers, psychiatrists, and dietitians. Specific team composition would depend on the objective of therapy: speech and language pathologists would be involved in assessing and treating aphasia, dysarthria, and swallowing; a physical therapist is likely to be involved in the assessment and treatment of problems of movement and function; an occupational therapist is likely to be involved in helping to recuperate the ability to perform activities of daily living (ADLs). Assessments should be made using standardized clinical criteria.

A certain degree of caution must be used when incorporating the recommendations of guidelines. In particular, the date of the guideline is important to consider, as the evidence upon which these recommendations are based may no longer be current. Moreover, it is important to consider which subgroup of patients the guideline addresses. For example, some guidelines may focus on recommendations for persons who are older and may not take into account the issues specific to younger stroke patients, with milder manifestations of stroke symptoms and with less comorbidities.

Rehabilitation therapy should be a goal-driven process, with goals set by patients, families, and care teams. Short- and long-term goals must be tailored to specific patient needs. These goals should involve early mobilization to prevent complications from stroke. Mobilization and activity levels should increase progressively as long as medically tolerated. The aim is to engage persons with stroke in the maximum daily amount of goal-focused activity that can be tolerated in a 7-day period.

The appropriate treatment setting for rehabilitation therapy should be driven by goals and the therapeutic regimen. For example, a regimen involving the use of specialized, fixed equipment would have to take place in a rehabilitation centre, while an exercise-based regimen could be performed in a patient’s home. Drug therapy may be a part of this regimen.

When considering what should be in a comparative treatment, recommendations from clinical practice guidelines may be an important source for defining a good comparator treatment (relative to a new therapy). Two sets of guidelines provide more specific recommendations for stroke rehabilitation therapy. Guidelines from the United States Department of Veterans Affairs50 algorithmically delineate the specific steps that should be taken to assess a patient prior to the commencement of rehabilitation. The guidelines additionally list the steps to follow during in-patient or community rehabilitation. These guidelines may be considered a template for standard therapy, but they are assessment-driven in the sense that they recommend what to assess (e.g., communication, motor function), but do not indicate the specific tool, device, or procedure to use to make the assessment. They would not be informative to judge whether the precise interventions used in standard therapy in a study would be a valid comparator.

The second set of guidelines, produced by the American Heart Association, is for a rehabilitation exercise program designed to help improve functional motor performance.51 This set of guidelines is an exception to the norm because it lays out specific modes of exercise, provides information on intensity, frequency, and duration of therapy, and lists major goals for patients. Such detailed guidelines, if they were to exist for other areas in the realm of stroke rehabilitation, would serve to define valid comparator treatments.

Another group of guidelines in stroke rehabilitation, published by the National Guideline Clearinghouse (http://www.guideline.gov), summarizes the level of evidence for specific treatment approaches. For example, a set of clinical practice guidelines for balance training52 reports Grade A evidence for a combination therapy of balance training and visual feedback, versus task-specific training, to improve standing balance over a 2 week followup period. The utility of guidelines such as these is that researchers can assess the level of evidence for certain treatments (e.g., Grade A evidence as defined in these guidelines means that minimum clinically important differences of greater than 15 percent have been observed in at least one RCT). However, there is no prescriptive direction in these guidelines to detail the most appropriate circumstances for using any given treatment.

Clinical practice guidelines in stroke rehabilitation may not, to date, be a comprehensive source for assessing the appropriateness of comparator therapies. Researchers in the field of stroke rehabilitation must establish the adequacy of a comparator on a study by study basis, preferably through the help of an expert such as a trained professional with practical experience who works in rehabilitation, (e.g., a therapist who treats patients in the domain of interest). For researchers who review the literature, it is highly recommended that they include such persons on the research team.

### Evaluating Outcome Measures in Stroke Rehabilitation

The assessment of outcomes in stroke is done using outcome measurement instruments. These instruments typically require a patient or proxy, such as a relative of the patient, to answer a series of questions about a specific topic like the ability to perform ADLs. Responses are usually multiple choice (very good/good/poor) or Likert-type scales (1 = poor health; 7 = excellent health). Some instruments are administered by an interviewer and others are completed by the patients themselves. There are also instruments that require patients to perform an activity (e.g., climb a set of stairs while being timed). The answers to the questions, or performance on the activity, are usually assigned a score; the total score after adding together all question- or performance-specific scores represents the level or intensity of an outcome. For example, the Barthel Index1 contains 10 questions designed to measure a person’s daily functioning. The overall score on the index could range from 0 (complete dependence) to 100 (complete independence). A subject’s score on the index represents her level of daily functioning. Numerous outcome measures have been developed specifically for stroke (e.g., Scandinavian Stroke Scale53), while others are used in stroke even though their original purpose was for a different therapeutic domain (e.g., Mini-Mental State Examination54).

Before an outcome measurement instrument is used in stroke rehabilitation, it must be verified to ensure that it is suitable for measuring outcomes in persons with stroke. This verification is an absolute prerequisite for instruments developed specifically for use in stroke rehabilitation. Instruments developed and verified in other areas of health care must be reverified in stroke patients before they can be used in stroke rehabilitation studies. A measure developed in another area might not be adaptable to the many different and specific nuances of stroke.

The verification of the suitability of an instrument is done through the study of its psychometric properties: reliability, validity, and responsiveness to change.55 Reliability or reproducibility is the extent to which a measure produces the same result each time it is employed, provided the underlying phenomenon being measured is unchanged. Interrater reliability involves two or more raters who use the outcome measure to independently assess the same subject at the same point in time. Test-retest reliability involves the injection of temporality into the notion of reproducibility: subjects are evaluated twice with the same measure, but at two different points in time. Reliability is high when the results of the separate evaluations are quite similar to one another. A third type of reliability is called ‘internal consistency’, or the extent to which the subcomponents of a scale all measure the same construct.

Validity is the extent to which the outcome measure adequately captures what it is intended to measure. For example, if the score on an index of ADLs represents actual physical function, then the index would be considered valid. There are three general types of validity: content, construct, and criterion. Content validity concerns the extent to which the outcome measure covers the scope of the construct under study. For example, does the ADL index contain all activities that are necessary to adequately measure physical function?

Construct validity refers to the theoretical linkage between an outcome measure and the construct. If persons with decreased physical function post-stroke have lower scores on the ADL index (assuming lower scores indicate reduced ability to perform ADLs), then the measure can be said to have construct validity. However, if there was an inverse association between physical function and index score, then the outcome measure might be flawed (invalid) or the hypothesized relationship between physical function and ADLs might not bear truth in reality. Criterion validity concerns the extent to which an outcome measure correlates with a ‘gold standard’.

Responsiveness is an outcome measure’s ability to accurately detect clinically meaningful change. These changes are typically specified using the minimal clinically important difference (MCID), which is the smallest difference in efficacy between treated and untreated groups that could be considered clinically significant.56 Responsiveness to change may be assessed with the standardized response mean (SRM), which is the mean score change divided by the standard deviation of the change.55 SRMs between 0.2 and less than 0.5 are small, between 0.5 and less then 0.8 are moderate, and 0.8 or greater are large.57 The higher the SRM, the greater the likelihood that the outcome measure captures actual changes that occur because of treatment. Note that evaluation of responsiveness may not be applicable to outcomes of events, such as recurrences of a new stroke.

In research to evaluate stroke rehabilitation therapies, outcome measures should only be selected if they have strong psychometric properties established in stroke patients. Before the selection of specific measures, though, researchers must identify a broader series of outcome domains that will be of interest in their studies. These domains are essentially the constructs that individual measures will describe. The ICF30 may be used as a guide to help link outcome domains with specific outcome measures.4,6,20

In general, outcomes measuring impairment (e.g., cognition) should be included in studies of stroke rehabilitation therapies because impairment is most closely linked to volume of brain activity and prognosis (ICF category B1 – mental functions). However, functional outcome measures (e.g., ICF category B114 – orientation functions) should also be included because persons recovering from stroke are interested in regaining as much normal function as possible.3 The primary outcome measure should be “modality-specific”, rather than generic, and matched to the most important treatment objective of the study. The ‘modality-specific’ nature of the selected measure is necessary to reflect the fact that the rate and extent of post-stroke recovery differs by outcome domain.58

When selecting outcome measures, it is important to consider stroke severity and the natural history of stroke recovery, as well as the mode of administration of the measure (interviewer or self-rated). Outcomes can be measured at three months in efficacy studies and at six months in effectiveness studies.8 Outcomes should not be dichotomized (e.g., improved by 2 points or improved by less than 2 points) because recovery from stroke is variable across a continuum and often defined individually through goal setting and attainment.8

The selection of outcome measures for stroke rehabilitation studies cannot be prescribed with an algorithm. Researchers must be guided by the general principles enumerated in the above discussion. The specific choice of measure will be driven by the outcome under evaluation. The measure should be reliable and valid, and responsive to change, in stroke patients. Other issues related to the study (e.g., design, length of followup) will also play a role in selecting outcomes.

We speculate that space restrictions in journals often prevent authors from fully explaining the rationale behind their selection of outcomes. Therefore, reviewers of stroke rehabilitation studies will need to be familiar with the outcome measures used in the rehabilitation field. Although the most popular outcome measures in stroke rehabilitation have been tabulated,58,59 reviewers should not judge the appropriateness of these measures based solely on the frequency of use. In the ICF domain of participation (i.e., ability to partake in life situations), the top three outcome measurement instruments by frequency of use (EuroQoL-5D, Medical Outcomes Study Short Form 36, Nottingham Health Profile)58 are generic health measures that may not capture the nuances of such a widely diverse area. This is especially so if a study is focused on one precise aspect of participation (e.g., ability to engage in paid employment).

### Key Methodological Points to Remember

Key methodological points to remember when evaluating stroke rehabilitation studies include:

1. RCTs or high-quality observational studies (e.g., cohort, case control studies) are the ideal study design;
2. Subjects should be sampled from the population in which the new therapy will be used;
3. The sample characteristics of subjects should be presented in a table (stratified by treatment group);
4. Prior and concurrent treatments should be described to assess whether study participants received atypical treatments that could affect their response to rehabilitation therapy;
5. The new therapy must be clearly described and evaluated in conjunction with a comparison therapy, which should also be clearly described;
6. Authors should report the timing, frequency, and duration of the interventions in their study, plus the type of person conducting the intervention (e.g., physical therapist) and the nature of the intervention itself (e.g., describe devices used in therapy, describe exercise programs). This detail should also be provided for the comparison therapy
7. The comparison therapy should be clinically relevant and clinically routine;
8. Study outcomes should be clearly defined and linked to the objective of the rehabilitation therapy under consideration;
9. The primary outcome measure should be “modality-specific”, rather than generic, and matched to the most important treatment objective of the study;
10. Participants outcomes must be correctly assessed (e.g., avoid using outcome measures with floor or ceiling effects);
11. Outcome measurement instruments should only be selected if they have strong psychometric properties in stroke patients (reliability, validity, responsiveness to change);
12. ICF categories can be used as a guide to help select outcome measurement instruments;
13. Instruments measuring impairment (e.g., level of cognition) and function, including ability to participate in activities, should be included in studies of stroke rehabilitation therapies;
14. During followup, participants should be evaluated in an objective and identical manner regardless of the intervention received; and
15. Length of followup should be long enough to show improvement in the primary outcome domain of interest.

### Key Question

An overarching, key research question for this technology assessment was derived in consultation with the Agency for Healthcare Research and Quality’s (AHRQ’s) task order officer and representatives of CMS. CMS instructed that the relevant aspects of the research question had to focus on two important issues related to the evaluation of new rehabilitation therapies, i.e., study design and selection of outcome measures. The focus of the technology assessment was not to be on treatment efficacy.

CMS was particularly interested in identifying literature that addressed the selection or characteristics of stroke outcomes in six domains: ambulation, quality of life (including caregiver burden), activities of daily living, cognition, speech and communication, and swallowing and dysphagia. Of special importance was the need to evaluate the psychometric properties (particularly, the MCID) of these outcomes when used in comparative studies in these domains. Another important item to examine was the classification of these outcomes within the ICF taxonomy. As such, a secondary objective of this technology assessment was to undertake a critical appraisal of the adequacy of the outcomes used in stroke rehabilitation studies.

Taking into account the needs of CMS, the overarching research question for this technology assessment was: “What are the key methodological issues (internal validity) in comparative studies designed to assess rehabilitation therapies administered to stroke patients?” A secondary purpose of the assessment was to critically appraise the adequacy of outcome measures used to capture the six domains of interest.

The consultation process with AHRQ and CMS also identified 10 key attributes of studies that would be evaluated to address the overarching research question. These attributes included:

1. Study design (e.g., randomized controlled trial, observational study, etc.);
2. Randomization and blinding;
3. Patient selection criteria and characteristics;
4. Characteristics of personnel performing the intervention (including training needed);
5. Timing of the intervention relative to the stroke;
6. Frequency and duration of the intervention;
7. Length of followup in the trial and durability of benefit;
8. Prior and concurrent treatments in relation to the studied intervention;
9. Comparator used and relationship of the comparator to current best practices in stroke rehabilitation; and
10. Outcome measures used;
  a. Relation to ICF domains;
  b. Reliability, validity, and reproducibility; and
  c. MCID.