# Excluded Studies

Hyndman D, Ashburn A, Yardley L, Stack E. Interference between balance, gait and cognitive task performance among people with stroke living in the community. Disability & Rehabilitation. 2006;28(13–14):849-856. [pmid: 16777772].
Lennon O, Carey A, Stephenson J, Gaffney N, Blake C. A single-blinded, randomised, controlled trial to evaluate the effects of a cardiac rehabilitation programme for the non-acute ischaemic stroke population. Physical Therapy Reviews. 2006;11(3):211-212. Ref ID: 30.
Muro MJ, Pedro-Cuesta J, Almazan J, von Koch L, Holmqvist LW. Outcome and use of health care in patients with moderate impairment and stroke in south Madrid and southwest Stockholm. Journal of Stroke and Cerebrovascular Diseases. 2005;14(4):167-173. [pmid: 17904020].
Hartman-Maeir A, Soroker N, Oman SD, Katz N. Awareness of disabilities in stroke rehabilitation—a clinical trial. Disability and Rehabilitation. 2003;25(1):35-44. [pmid: 12554390].
Schindler I, Kerkhoff G, Karnath HO, Keller I, Goldenberg G. Neck muscle vibration induces lasting recovery in spatial neglect. [see comment]. Journal of Neurology, Neurosurgery & Psychiatry. 2002;73(4):412-419.
Bragoni M, Altieri M, Di PV, Padovani A, Mostardini C, Lenzi GL. Bromocriptine and speech therapy in non-fluent chronic aphasia after stroke. Neurological Sciences. 2000;21(1):19-22. [pmid: 10938198].
Paolucci S, Matano A, Bragoni M, Coiro P, De Angelis D, Fusco FR, et al. Rehabilitation of left brain-damaged ischemic stroke patients: the role of comprehension language deficits. A matched comparison. Cerebrovascular Diseases. 2005;20(5):400-406. [pmid: 16205059].
Pedersen PM, Vinter K, Olsen TS. Improvement of oral naming by unsupervised computerised rehabilitation. [References]. Aphasiology. 2001;15(2):151-169.
Whiting E, Chenery HJ, Chalk J, Copland DA. Dexamphetamine boosts naming treatment effects in chronic aphasia. [References]. Journal of the International Neuropsychological Society. 2007;13(6):972-979. [pmid: 17942015].
Kiger M, Brown CS, Watkins L. Dysphagia management: an analysis of patient outcomes using VITALSTIM therapy compared to traditional swallow therapy. Dysphagia. 2006;21(4):243-253. [pmid: 17216386].
Seki T, Kurusu M, Tanji H, Arai H, Sasaki H. Acupuncture and swallowing reflex in poststroke patients. Journal of the American Geriatrics Society. 2003;51(5):726-727. [pmid: 12752859].

## Excluded Studies from Review of Reviews

1 Barclay GR, Stevenson T, Poluha W, Moffatt MEK, Taback SP. Force platform feedback for standing balance training after stroke. SO: Barclay-Goddard R, Stevenson T, Poluha W, Moffatt MEK, Taback SP Force platform feedback for standing balance training after stroke. Cochrane Database of Systematic Reviews: Reviews. 2004;2004(4).
2 Kwan J, Sandercock P. In-hospital care pathways for stroke. SO: Kwan J, Sandercock P. In-hospital care pathways for stroke. Cochrane Database of Systematic Reviews: Reviews. 2004;(4).
3 West C, Hesketh A, Vail A, Bowen A. Interventions for apraxia of speech following stroke. SO: West C, Hesketh A, Vail A, Bowen A Interventions for apraxia of speech following stroke. Cochrane Database of Systematic Reviews: Reviews. 2005;(4).
4 Outpatient-Service. Therapy-based rehabilitation services for stroke patients at home. SO: Outpatient Service Trialists Therapy-based rehabilitation services for stroke patients at home. Cochrane Database of Systematic Reviews: Reviews. 2003;(1).
5 Prvu Bettger JA, Stineman MG. Effectiveness of multidisciplinary rehabilitation services in postacute care: state-of-the-science. A review. [Review] [64 refs]. Archives of Physical Medicine & Rehabilitation. 2007;88(11):1526-1534. [pmid: 17964900].
6 Legg L, Drummond A, Leonardi-Bee J, Gladman JR, Corr S, Donkervoort M, et al. Occupational therapy for patients with problems in personal activities of daily living after stroke: systematic review of randomised trials. [see comment]. [Review] [13 refs]. BMJ. 2007;335(7626):922. [pmid: 17901469].
7 Shiflett SC. Does acupuncture work for stroke rehabilitation: what do recent clinical trials really show?. [Review] [26 refs]. Topics in Stroke Rehabilitation. 2007;14(4):40-58. [pmid: 17698457].
8 Pollock A, Baer G, Langhorne P, Pomeroy V. Physiotherapy treatment approaches for the recovery of postural control and lower limb function following stroke: a systematic review. [Review] [56 refs]. Clinical Rehabilitation. 2007;21(5):395-410. [pmid: 17613560].
9 Bowen A, Lincoln NB. Cognitive rehabilitation for spatial neglect following stroke. [update of Cochrane Database Syst Rev. 2002;(2):CD003586; PMID: 12076489]. [Review] [61 refs]. Cochrane Database of Systematic Reviews. 2007;(2):CD003586. [pmid: 17443528].
10 Langhorne P, Holmqvist LW. Early Supported DT. Early supported discharge after stroke. [erratum appears in J Rehabil Med. 2007 Apr;39(3):269]. [Review] [21 refs]. Journal of Rehabilitation Medicine. 2007;39(2):103-108. [pmid: 17351690].
11 Foley N, Salter K, Teasell R. Specialized stroke services: a meta-analysis comparing three models of care. Cerebrovascular Diseases. 2007;23(2–3):194-202. [pmid: 17143003].
12 Pollock A, Baer G, Pomeroy V, Langhorne P. Physiotherapy treatment approaches for the recovery of postural control and lower limb function following stroke. [update of Cochrane Database Syst Rev. 2003;(2):CD001920; PMID: 12804415]. [Review] [128 refs]. Cochrane Database of Systematic Reviews. 2007;(1):CD001920. [pmid: 17253468].
13 Legg LA, Drummond AE, Langhorne P. Occupational therapy for patients with problems in activities of daily living after stroke. [Review] [74 refs]. Cochrane Database of Systematic Reviews. 2006;(4):CD003585. [pmid: 17054178].
14 Cicerone KD, Dahlberg C, Malec JF, Langenbahn DM, Felicetti T, Kneipp S, et al. Evidence-based cognitive rehabilitation: updated review of the literature from 1998 through 2002. [see comment]. [Review] [117 refs]. Archives of Physical Medicine & Rehabilitation. 2005;86(8):1681-1692. [pmid: 16084827].
15 Langhorne P, Dey P, Woodman M, Kalra L, Wood-Dauphinee S, Patel N, et al. Is stroke unit care portable? A systematic review of the clinical trials. [Review] [14 refs]. Age & Ageing. 2005;34(4):324-330. [pmid: 15955755].
16 Smidt N, de Vet HC, Bouter LM, Dekker J, Arendzen JH, de Bie RA, et al. Effectiveness of exercise therapy: a best-evidence summary of systematic reviews. [see comment]. [Review] [133 refs]. Australian Journal of Physiotherapy. 2005;51(2):71-85. [pmid: 15924510].
17 Hopwood V, Lewith GT. Does acupuncture help stroke patients become more independent?. [Review] [12 refs]. Journal of Alternative & Complementary Medicine. 2005;11(1):175-177.
18 Langhorne P, Taylor G, Murray G, Dennis M, Anderson C, Bautz-Holter E, et al. Early supported discharge services for stroke patients: a meta-analysis of individual patients’ data. [see comment]. Lancet. 2005;365(9458):501-506. [pmid: 15705460].
19 van Peppen RP, Kwakkel G, Wood-Dauphinee S, Hendriks HJ, Van der Wees PJ, Dekker J. The impact of physical therapy on functional outcomes after stroke: what’s the evidence?. [Review] [230 refs]. Clinical Rehabilitation. 2004;18(8):833-862. [pmid: 15609840].
20 Kwakkel G, van Peppen R, Wagenaar RC, Wood DS, Richards C, Ashburn A, et al. Effects of augmented exercise therapy time after stroke: a meta-analysis. [Review] [53 refs]. Stroke. 2004;35(11):2529-2539. [pmid: 15472114].
21 Kwan J, Sandercock P. In-hospital care pathways for stroke. [update of Cochrane Database Syst Rev. 2002;(2):CD002924; PMID: 12076460]. [Review] [84 refs]. Cochrane Database of Systematic Reviews. 2004;(4):CD002924. [pmid: 15495038].
22 Bolton DA, Cauraugh JH, Hausenblas HA. Electromyogram-triggered neuromuscular stimulation and stroke motor recovery of arm/hand functions: a meta-analysis. Journal of the Neurological Sciences. 2004;223(2):121-127. [pmid: 15337612].
23 Walker MF, Leonardi-Bee J, Bath P, Langhorne P, Dewey M, Corr S, et al. Individual patient data meta-analysis of randomized controlled trials of community occupational therapy for stroke patients. Stroke. 2004;35(9):2226-2232. [pmid: 15272129].
24 Kottink AI, Oostendorp LJ, Buurke JH, Nene AV, Hermens HJ, Ijzerman MJ. The orthotic effect of functional electrical stimulation on the improvement of walking in stroke patients with a dropped foot: a systematic review. [Review] [50 refs]. Artificial Organs. 2004;28(6):577-586. [pmid: 15153151].
25 Andrews PJ. Critical care management of acute ischemic stroke. [Review] [35 refs]. Current Opinion in Critical Care. 2004;10(2):110-115. [pmid: 15075720].
26 Legg L, Langhorne P. Outpatient Service. Rehabilitation therapy services for stroke patients living at home: systematic review of randomised trials. [see comment]. [Review] [25 refs]. Lancet. 2004;363(9406):352-356. [pmid: 15070563].
27 Morris SL, Dodd KJ, Morris ME. Outcomes of progressive resistance strength training following stroke: a systematic review. [Review] [50 refs]. Clinical Rehabilitation. 2004;18(1):27-39. [pmid: 14763717].
28 Lannin NA, Herbert RD. Is hand splinting effective for adults following stroke? A systematic review and methodologic critique of published research. [Review] [30 refs]. Clinical Rehabilitation. 2003;17(8):807-816. [pmid: 14682551].
29 Barreca S, Wolf SL, Fasoli S, Bohannon R. Treatment interventions for the paretic upper limb of stroke survivors: a critical review. [Review] [57 refs]. Neurorehabilitation & Neural Repair. 2003;17(4):220-226. [pmid: 14677218].
30 Jutai JW, Bhogal SK, Foley NC, Bayley M, Teasell RW, Speechley MR. Treatment of visual perceptual disorders post stroke. Topics in Stroke Rehabilitation. 2003;10(2):77-106. [pmid: 13680519].
31 Teasell RW, Bhogal SK, Foley NC, Speechley MR. Gait retraining post stroke. Topics in Stroke Rehabilitation. 2003;10(2):34-65. [pmid: 13680517].
32 Teasell RW, Foley NC, Bhogal SK, Speechley MR. Early supported discharge in stroke rehabilitation. Topics in Stroke Rehabilitation. 2003;10(2):19-33. [pmid: 13680516].
33 Foley NC, Teasell RW, Bhogal SK, Doherty T, Speechley MR. The efficacy of stroke rehabilitation: a qualitative review. Topics in Stroke Rehabilitation. 2003;10(2):1-18.
34 Moseley AM, Stark A, Cameron ID, Pollock A. Treadmill training and body weight support for walking after stroke. [update in Cochrane Database Syst Rev. 2005;(4):CD002840; PMID: 16235304]. [Review] [61 refs]. Cochrane Database of Systematic Reviews. 2003;(3):CD002840. [pmid: 12917932].
35 Bhogal SK, Teasell R, Speechley M. Intensity of aphasia therapy, impact on recovery. [see comment]. Stroke. 2003;34(4):987-993. [pmid: 12649521].
36 Steultjens EM, Dekker J, Bouter LM, van de Nes JC, Cup EH, van den Ende CH. Occupational therapy for stroke patients: a systematic review. [see comment]. [Review] [59 refs]. Stroke. 2003;34(3):676-687. [pmid: 12624291].
37 Meek C, Pollock A, Potter J, Langhorne P. A systematic review of exercise trials post stroke. Clinical Rehabilitation. 2003;17(1):6-13. [pmid: 12617374].
38 Outpatient Service. Therapy-based rehabilitation services for stroke patients at home. [Review] [71 refs]. Cochrane Database of Systematic Reviews. 2003;(1):CD002925. [pmid: 12535444].
39 Ada L, Foongchomcheay A. Efficacy of electrical stimulation in preventing or reducing subluxation of the shoulder after stroke: a meta-analysis. [Review] [39 refs]. Australian Journal of Physiotherapy. 2002;48(4):257-267. [pmid: 12443520].
40 Hendricks HT, van Limbeek J, Geurts AC, Zwarts MJ. Motor recovery after stroke: a systematic review of the literature. [Review] [93 refs]. Archives of Physical Medicine & Rehabilitation. 2002;83(11):1629-1637. [pmid: 12422337].
41 Sze FK, Wong E, Or KK, Lau J, Woo J. Does acupuncture improve motor recovery after stroke? A meta-analysis of randomized controlled trials. Stroke. 2002;33(11):2604-2619. [pmid: 12411650].
42 de Kroon JR, van der Lee JH, Ijzerman MJ, Lankhorst GJ. Therapeutic electrical stimulation to improve motor control and functional abilities of the upper extremity after stroke: a systematic review. Clinical Rehabilitation. 2002;16(4):350-360. [pmid: 12061468].
43 Trombly CA, Ma HI. A synthesis of the effects of occupational therapy for persons with stroke, Part I: Restoration of roles, tasks, and activities. American Journal of Occupational Therapy. 2002;56(3):250-259. [pmid: 12058514].
44 Turner-Stokes L, Jackson D. Shoulder pain after stroke: a review of the evidence base to inform the development of an integrated care pathway. [Review] [121 refs]. Clinical Rehabilitation. 2002;16(3):276-298. [pmid: 12017515].
45 Turner-Stokes L, Hassan N. Depression after stroke: a review of the evidence base to inform the development of an integrated care pathway. Part 1: Diagnosis, frequency and impact. [Review] [94 refs]. Clinical Rehabilitation. 2002;16(3):231-247. [pmid: 12017511].
46 Sellars C, Hughes T, Langhorne P. Speech and language therapy for dysarthria due to nonprogressive brain damage: a systematic Cochrane review. [Review] [25 refs]. Clinical Rehabilitation. 2002;16(1):61-68. [pmid: 11837527].
47 Bays CL. Quality of life of stroke survivors: a research synthesis. Journal of Neuroscience Nursing. 2001;33(6):310-316. [pmid: 11776713].
48 van der Lee JH. Constraint-induced therapy for stroke: more of the same or something completely different?. [Review] [37 refs]. Current Opinion in Neurology. 2001;14(6):741-744. [pmid: 11723382].
49 Doggett DL, Tappe KA, Mitchell MD, Chapell R, Coates V, Turkelson CM. Prevention of pneumonia in elderly stroke patients by systematic diagnosis and treatment of dysphagia: an evidence-based comprehensive analysis of the literature. [Review] [17 refs]. Dysphagia. 2001;16(4):279-295. [pmid: 11720404].
50 Park J, Hopwood V, White AR, Ernst E. Effectiveness of acupuncture for stroke: a systematic review. [Review] [31 refs]. Journal of Neurology. 2001;248(7):558-563. [pmid: 11517996].
51 Cole MG, Elie LM, McCusker J, Bellavance F, Mansour A. Feasibility and effectiveness of treatments for post-stroke depression in elderly inpatients: systematic review. Journal of Geriatric Psychiatry & Neurology. 2001;14(1):37-41. [pmid: 11281315].
52 van der Lee JH, Snels IA, Beckerman H, Lankhorst GJ, Wagenaar RC, Bouter LM. Exercise therapy for arm function in stroke patients: a systematic review of randomized controlled trials. [Review] [53 refs]. Clinical Rehabilitation. 2001;15(1):20-31. [pmid: 11237158].
53 Price CI, Pandyan AD. Electrical stimulation for preventing and treating post-stroke shoulder pain: a systematic Cochrane review. [Review] [35 refs]. Clinical Rehabilitation. 2001;15(1):5-19. [pmid: 11237161].
54 Langhorne P, Duncan P. Does the organization of postacute stroke care really matter?. Stroke. 2001;32(1):268-274. [pmid: 11136947].
55 Britton M, Andersson A. Home rehabilitation after stroke. Reviewing the scientific evidence on effects and costs. International Journal of Technology Assessment in Health Care. 2000;16(3):842-848. [pmid: 11028139].
56 Langhorne P. Organised inpatient (stroke unit) care for stroke. Stroke Unit Trialists’ Collaboration. [update in Cochrane Database Syst Rev. 2002;(1):CD000197; PMID: 11869570]. [Review] [33 refs]. Cochrane Database of Systematic Reviews. 2000;(2):CD000197. [pmid: 10796318].
57 Geurts AC, Visschers BA, van Limbeek J, Ribbers GM. Systematic review of aetiology and treatment of post-stroke hand oedema and shoulder-hand syndrome. [Review] [28 refs]. Scandinavian Journal of Rehabilitation Medicine. 2000;32(1):4-10. [pmid: 10782934].
58 Hajat C, Hajat S, Sharma P. Effects of poststroke pyrexia on stroke outcome : a meta-analysis of studies in patients. Stroke. 2000;31(2):410-414. [pmid: 10657414].
59 Therapy-based rehabilitation services for stroke patients at home. Cochrane Database of Systematic Reviews. 2007;(4):CD002925.
60 Kwan J, Sandercock P. In-hospital care pathways for stroke. Cochrane Database of Systematic Reviews. 2007;(4):CD002924.
61 Lincoln NB, Majid MJ, Weyman N. Cognitive rehabilitation for attention deficits following stroke. Cochrane Database of Systematic Reviews. 2007;(4):CD002842.
62 Discharge Trialists. Services for reducing duration of hospital care for acute stroke patients. Cochrane Database of Systematic Reviews. 2005;(4):CD000443. [pmid: 15846604].
63 Greener J, Enderby P, Whurr R. Speech and language therapy for aphasia following stroke. Cochrane Database of Systematic Reviews. 2007;(4):CD000425.
64 Bath PMW, Bath-Hextall FJ, Smithard DG. Interventions for dysphagia in acute stroke. Cochrane Database of Systematic Reviews. 2007;(4):CD000323.
65 Organised inpatient (stroke unit) care for stroke. Cochrane Database of Systematic Reviews. 2007;(4):CD000197. [pmid: 17943737].
66 das NR, Lincoln N. Memory rehabilitation following stroke: a systematic review of literature. Clinical Rehabilitation. 2006;20(8):734.
67 West C, Vail A, Hesketh A, Bowen A. Motor apraxia: is rehabilitation effective?. Clinical Rehabilitation. 2006;20(8):733.
68 Thomas L, Barrett J, Cross S, French B, Leathley M, Sutton C, et al. Prevention and treatment of urinary incontinence after stroke in adults: a systematic review for the Cochrane Collaboration. Clinical Rehabilitation. 2006;20(8):731-732.
69 Kwakkel G. Impact of intensity of practice after stroke: issues for consideration. Disability and Rehabilitation. 2006;28(13–14):823-830. [pmid: 16777769].
70 Fasoli SE, Krebs HI, Hogan N. Rehabilitation robotics for the paretic arm after stroke: an efficacy review. Neurorehabilitation and Neural Repair. 2005;19(4):368.
71 Boaro N, Velji K. Review: counselling and education may improve outcomes in caregivers of patients with stroke. Evidence-Based Nursing. 2005;8(4):119. [pmid: 16247900].
72 Foongchomcheay A, Ada L, Canning CG. Use of devices to prevent subluxation of the shoulder after stroke. Physiotherapy Research International. 2005;10(3):134-145. [pmid: 16245754].
73 Ly JV, Donnan GA. Review: early supported discharge reduces death or dependence after stroke. ACP Journal Club. 2005;143(2):30. [pmid: 16134904].
74 Page T, Lockwood C. Prevention and management of shoulder pain in the hemiplegic patient. JBI Reports. 2003;1(5):149-165.
75 Gallichio J, Kluding P. Virtual reality in stroke rehabilitation: review of the emerging research. Physical Therapy Reviews. 2004;9(4):207-212.
76 Rehabilitation therapy services for stroke patients living at home: systematic review of randomised trials. Lancet. 2004;363(9406):352-356. [pmid: 15070563].
77 Handy J, Salinas S, Blanchard SA, Aitken MJ. Meta-analysis examining the effectiveness of electrical stimulation in improving functional use of the upper limb in stroke patients. Physical and Occupational Therapy in Geriatrics. 2003;21(4):67-78.
78 Langhorne P. Review: comprehensive occupational therapy interventions improve outcomes after stroke. ACP Journal Club. 2004;140(1):7. [pmid: 14711278].
79 Vickers A. Acupuncture. Effective Health Care. 2001;7(2):1-11.
80 Manning CD, Pomeroy VM. Effectiveness of treadmill retraining on gait of hemiparetic stroke patients: systematic review of current evidence. Physiotherapy. 2003;89(6):337-349.
81 Hiraoka K. Rehabilitation effort to improve upper extremity function in post-stroke patients: a meta-analysis. Journal of Physical Therapy Science. 2001;13(1):5-9.
82 van der Lee JH, Snels IAK, Beckerman H, Lankhorst GJ, Wagenaar RC, Bouter LM. Exercise therapy for arm function in stroke patients: a systematic review of randomized controlled trials. Clinical Rehabilitation. 2001;15(1):20-31. [pmid: 11237158].
83 Chae J, Yu D. A critical review of neuromuscular electrical stimulation for treatment of motor dysfunction in hemiplegia. Assistive Technology. 2000;12(1):33-49. [pmid: 11067576].
84 Therapy-based rehabilitation services for stroke patients at home. [Systematic Review]. Cochrane Database of Systematic Reviews. 2007;(4). (4).
85 Services for reducing duration of hospital care for acute stroke patients. [Systematic Review]. Cochrane Database of Systematic Reviews. 2007;(4). (4).
86 Saunders DH, Greig CA, Young A, et al. Physical fitness training for stroke patients. [Systematic Review]. Cochrane Database of Systematic Reviews. 2007;(4). (4).
87 Organised inpatient (stroke unit) care for stroke. [Systematic Review]. Cochrane Database of Systematic Reviews. 2007;(4). (4).
88 Anderson CS, Hackett ML, House AO. Interventions for preventing depression after stroke. [Systematic Review]. Cochrane Database of Systematic Reviews. 2007;(4). (4).
89 Pomeroy VM, King L, Pollock A, et al. Electrostimulation for promoting recovery of movement or functional ability after stroke. [Systematic Review]. Cochrane Database of Systematic Reviews. 2007;(4). (4).
90 van Dijk H, Hermens HJ. Distance training for the restoration of motor function. [Review] [26 refs]. Journal of Telemedicine & Telecare. 2004;10(2):63-71. [pmid: 15068640].