# Extraction Criteria for Systematic Reviews

## Search Methods (Maximum score _ 4)

1. Were the search methods used to find evidence (primary studies) on the primary question(s) stated?

- 2 points: Yes—includes description of databases searched, search strategy, and years reviewed; described well enough to duplicate.
- 1 point: Partially—partial description of methods, but not sufficiently to duplicate search.
- 0 points: No—no description of search methods.

2. Was the search for evidence reasonably comprehensive?

- 2 points: Yes—must include at least one computerized database search as well as search of unpublished or nonindexed literature (e.g., manual searches or letters to primary authors).
- 1 point: Can’t tell—search strategy partially comprehensive (e.g., one of the strategies above was performed)
- 0 points: No—search not comprehensive or not described well enough to make a judgment.

## Selection Methods (Maximum score _ 4)

3. Were the criteria used for deciding which studies to include in the review reported?

- 2 points: Yes—inclusion/exclusion criteria clearly defined.
- 1 point: Partially—reference to inclusion/exclusion criteria can be found in article but are not defined clearly enough to duplicate.
- 0 points: No—no criteria defined.

4. Was bias in the selection of articles avoided?

- 2 points: Yes—key issues influencing selection bias were dealt with; two of three of the following bias avoidance strategies were used:
  - (i) two or more assessors independently judged study relevance and selection using predetermined criteria; (ii) reviewers were blinded to identifying features of study [i.e., journal title, author(s), funding source]; (iii) assessors were blinded to treatment outcome.
- 1 point: Can’t tell—if only one of the three strategies above were used.
- 0 points: No—selection bias not avoided or not discussed.

## Validity Assessment (Maximum score _ 4)

5. Were the criteria used for assessing the validity of the studies that were reviewed reported?

- 2 points: Yes—criteria defined explicitly.
- 1 point: Partially—some discussion or reference to criteria but not sufficiently described to duplicate.
- 0 points: No—validity or methodologic quality criteria not used or not described.

6. Was the validity for each study cited assessed using appropriate criteria (either in selecting studies for inclusion or in analyzing the studies that are cited)?

- 2 points: Yes—the criteria used address the major factors influencing bias (e.g., population, intervention, outcomes, follow-up).
- 1 point: Partially—some discussion of methodologic review strategy but not clearly described with predetermined criteria.
- 0 points: No—criteria not used or not described.

## Synthesis (Maximum score _ 6)

7. Were the methods used to combine the findings for the relevant studies (to reach a conclusion) reported?

- 2 points: Yes—qualitative or quantitative methods are acceptable. 1 point: Partially—partial description of methods to combine/tabulate; not sufficient to duplicate. 0 points: Methods of combining studies not stated or described.

8. Were findings of relevant studies combined appropriately relative to the primary question the review addresses?

- 2 points: Yes—combining of studies appears acceptable.
- 1 point: Can’t tell—if in doubt, mark “can’t tell.”
- 0 points: No—no attempt was made to combine findings, and no statement was made regarding the inappropriateness ofcombining findings; if a summary (general) estimate was given anywhere in the abstract, the discussion, or the summary section of the article, and it was not reported how that estimate was derived, mark “no” even if there is a statement regarding the limitations of combining the findings of the studies reviewed.

9. Were the conclusions made by the author(s) supported by the data or analysis reported in the review?

- 2 points: Yes—data, not just citations, were reported that support the main conclusions regarding the primary question(s) that the overview addresses
- 1 point: Partially
- 0 points: No—conclusions not supported or unclear.
- How would you rate the methodologic quality for this review?
- Add up the scores from questions 1–9. Maximum quality score is 18 points.

Criteria used to assess methodologic quality of selected review articles. Adapted with permission from Hoving JL, Gross AR, Gasner D, et al. A critical appraisal of review articles on the effectiveness of conservative treatment for neck pain. Spine. 2001;26:196. [pmid: 11154541]. .