# Review of Reviews’ Tables

Table E1 Cochrane Reviews

Table E2 Non-Cochrane Reviews