# Outcome Tables

Table D1 Outcome measurement instruments used in Ambulation studies^*^

Outcome | Mode of Administration^**^ | Frequency in studies | ICF domain | Reliability in Stroke | Validity in Stroke | Tested for Responsiveness | MCID in stroke | Range of follow up time for studies | Study Author
Fugl-Meyer | Observation performance | 3 | Function44,51 | Yes | Yes | Yes | NR | 4 weeks to 6 month | Sutbeyaz135 Yavuzer141 Thaut137
Modified Ashworth Scale (MAS) | Performance | 2 | Function51 | Yes | Yes | Yes | NR | 0–6 months | Sutbeyaz135 Chen128
Scandinavian Stroke Scale | NR | 1 | Function44,52 | Yes | Yes | Yes | NR | 1–52 weeks | Askim125
Motricity Index | NR | 2 | Function52 | Yes | Yes | Yes | NR | 4–9 weeks | Mayr131 Tong138
10-metre walking test | NR | 6 | Activity44 | Yes | Yes | Yes | NR | 2 weeks–6 month | Peurala133 Chen128 Bayram127 Peurala134 Mayr131 Bayouk126
Barthel Index | Self report, observation/performance, proxy | 2 | Activity44,51,52 | Yes | Yes | Yes | NR | 3–4 weeks | Tong138 Thaut137
Berg Balance Scale (BBS) | Performance | 5 | Activity51 | Yes | Yes | Yes | NR | 1–52 weeks | Askim125 Marigold60 Tong138 English129 Pang132
Functional Independence Measure (FIM) | Interview, proxy | 4 | Activity51 | Yes | Yes | Yes | NR | 4 weeks–6 month | Sutbeyaz135 Peurala133 Peurala134 Tong138
Functional Ambulation Categories (FAC) | Interview/Observation | 2 | Activity51 | Yes | Yes | Yes | NR | 4 weeks to 6 months | Sutbeyaz135 Tong138
Time up and go (TUG) | Observation/performance | 2 | Activity51 | Yes | Yes | Yes | NR | 8 weeks to 1 year | Marigold60 Yan139
Rivermead Motor Assessment Scale | NR | 1 | Activity9 | Yes | Yes | Yes | Yes | 9 weeks | Mayr131
6-minute walk test (6MWT) | NR | 4 | Activity9 | Yes | Yes | Yes | NR | 0–6 months | Mayr131 Peurala133 Macko130 Pang132
5-minute walk test (5MWT) | NR | 2 | Activity16 | Yes | Yes | Yes | NR | 6 months to 52 weeks | Askim125 English129
2-minute walk test (2MWT) | NR | 1 | Activity16 | Yes | Yes | Yes | NR | 6 months | English129
Activities Balance confidence (ABC) | NR | 1 | Activity16 | Yes | Yes | Yes | NR | 1 year | Marigold60
Kinematic characteristics of gait | NR | 1 | Function16 | Yes | Yes | Yes | NR | 8 weeks | Yavuzer141
Rivermead Mobility Index (RMI) | NR | 1 | Activity16 | Yes | Yes | Yes | NR | 6 months | Macko130
Gait velocity | NR | 1 | Activity16 | Yes | Yes | Yes | NR | 3 weeks | Thaut137
Biomechanical measurements-3 dimensional gait analysis, walking velocity, cadence, step length and single support time, pelvic excursion, excursion of paretic hip, knee and ankle in saggital plane | NR | 1 | Function16 | Yes | Yes | Yes | NR | 8 weeks | Yavuzer141
Gait Assessment | NR | 1 | Function16 | Yes | Yes | Yes | NR | 29 weeks | Peurala134
Preferred walking (walking speed, cadence, stride time, stride length, and temporal symmetry index) | NR | 1 | Function16 | Yes | Yes | Yes | NR | 4 weeks | Yang140
Walking carrying a tray with glasses (walking speed, cadence, stride time, stride length, and temporal symmetry index) | NR | 1 | Function16 | Yes | Yes | Yes | NR | 4 weeks | Yang140
Composite Spasticity Score | NR | 1 | NR | NR | NR | NR | NR | 4 weeks | Yan139
Displacement of the Center of Pressure | NR | 1 | NR | NR | NR | NR | NR | 8 weeks | Bayouk126
Postural Sway | NR | 2 | NR | NR | NR | NR | NR | 0–6 months | Bayouk126 Peurala133
5 meter walk speed | NR | 1 | NR | NR | NR | NR | NR | 4 weeks | Tong138
Asymmetry in step length | NR | 1 | NR | NR | NR | NR | NR | NR | Roerdink63
Cadence | NR | 1 | NR | NR | NR | NR | NR | 3 weeks | Thaut137
Clonus Score | NR | 1 | NR | NR | NR | NR | NR | 12 weeks | Bayram127
Elderly mobility scale (EMS) | NR | 1 | NR | NR | NR | NR | NR | 4 weeks | Tong138
EU-Walking Scale | NR | 1 | NR | NR | NR | NR | NR | 9 weeks | Mayr131
Global Assessment of Spasticity Scale | NR | 1 | NR | NR | NR | NR | NR | 12 weeks | Bayram127
Interlimb Coordination and Auditory Motor Coordination | NR | 1 | NR | NR | NR | NR | NR | NR | Roerdink63
Iowa Level of Assistance Scale | NR | 1 | NR | NR | NR | NR | NR | 6 month | English129
Lower limb spasticity and muscle force | NR | 1 | NR | NR | NR | NR | NR | 29 weeks | Peurala133
Maximum Isometric Voluntary Contraction of ankle | NR | 1 | NR | NR | NR | NR | NR | 4 weeks | Yan139
Medical Research Council Scale | NR | 1 | NR | NR | NR | NR | NR | 9 weeks | Mayr131
Range of motion of ankle | NR | 1 | NR | NR | NR | NR | NR | 12 weeks | Bayram134
Step reaction time | NR | 1 | NR | NR | NR | NR | NR | 1 year | Marigold60
Step time | NR | 1 | NR | NR | NR | NR | NR | NR | Roerdink63
Stride length | NR | 1 | NR | NR | NR | NR | NR | 3 weeks | Thaut137
Swing symmetry | NR | 1 | NR | NR | NR | NR | NR | 3 weeks | Thaut137
Modified Motor Assessment Scale (mMAS) | NR | 2 | NR | NR | NR | NR | NR | 29 weeks | Peurala133 Peurala134
Functional Ambulation Profile (FAP) | NR | 1 | NR | NR | NR | NR | NR | 29 weeks | Peurala134
Ashworth Scale | NR | 2 | Function52 | No | No | No | NR | 9 to 12 weeks | Mayr131 Bayram127

Abbreviations: ICF=International classification of functioning, disability and health; NR=Not reported

* Psychometric properties of outcomes measures established for use in stroke patients not specific domains of functions (e.g ambulation) (Refers to all tables in this Appendix).

** This report did not examine if a link existed between an instrument’s psychometric properties and mode administration (e.g self-report, proxy) (Refers to all tables in this Appendix).

Table D2 Outcome measurement instruments used in Quality of Life studies^*^

Outcome | Mode of Administration^**^ | Frequency in studies | ICF domain | Reliability in Stroke | Validity in Stroke | Tested for Responsiveness | MCID in stroke | Range of follow up time for studies | Study Author
Nottingham Health Profile (NHP) | Self, interviewer | 3 | Participation43,51 | Yes | Yes | NR | NR | 12–52 weeks | Askim143 Fjaertof147 Wayne158
Stroke Adapted Sickness Impact Profile (SA-SIP30) | Self, interviewer | 2 | Participation43,51 | Yes | Yes | Yes | NR | 14–52 weeks | Hafsteinsdottir149 McClellan155
Stroke Specific Quality of Life scale (SSQOL): | Interviewer proxy | 1 | Participation43,51 | Yes | Yes | Yes | NR | 12 months | Kendall152
Subscales of the stroke impact scale (SIS) | Self, interviewer, proxy | 1 | Participation43,51 | Yes | Yes | Yes | Yes | 6 months | Studenski157
Medical Outcomes Study 36-item short form heath survey (SF-36) | Self, interviewer, proxy, telephone | 3 | Participation51 | Yes | Yes | Yes | NR | 6–24 months | Johnson150 Childers146 Studenski157
Center for Epidemiological Surveys Depression (CES-D) | NR | 1 | Function9 | Yes | Yes | Yes | NR | 12 weeks | Wayne158
Geriatric Depression Scale (GDS) | Interview, proxy | 1 | Function9,51 | Yes | Yes | Yes | NR | 6 months | Leeds153
National Institutes of Health Stroke Scale (NIHSS) | Observation/performance | 1 | Function44,51,52 | Yes | Yes | No | NR | 2 weeks | Park64
Mini-Mental State Examination (MMSE): | Observation/performance | 1 | Function51 | Yes | Yes | Yes | NR | 52 weeks | Fjaertof147
Modified Ashworth Scale | Performance | 3 | Function51 | Yes | Yes | NR | NR | 12–24 weeks | Wayne158 Johnson150 Childers146
Motricity Index (MI) | NR | 2 | Function9,52 | Yes | Yes | NR | NR | 2 weeks–6months | GAPS Group148 Park64
Ashworth scale | NR | 1 | Function52 | No | No | No | NR | 2 weeks | Park64
Rankin Scale | NR | 1 | Activity44,52 | Yes | Yes | Yes | NR | 12 months | Kalra151
10-meter walk | NR | 1 | Activity44 | Yes | Yes | Yes | NR | 2 weeks | Park64
Rivermead Motor Assessment (RMA): | NR | 1 | Activity9 | Yes | Yes | Yes | Yes | 16 weeks | Johnson150
Rivermead Mobility Index (RMI): | NR | 1 | Activity16 | Yes | Yes | Yes | NR | 6 months | GAPS Group148
Walking speed | NR | 2 | Activity16 | Yes | Yes | Yes | NR | 16 weeks–6 months | GAPS Group148 Johnson150
Mobility milestones: | NR | 1 | Activity16 | Yes | Yes | Yes | NR | 6 months | GAPS Group148
Frenchay Activity Index | Interview, proxy | 3 | Activity51 | Yes | Yes | Yes | NR | 3–12 months | Fjaertof147 Kalra151 Ryan156
Nine-Hole Peg Test (NHPT) | Performance | 1 | Activity51 | Yes | Yes | Yes | NR | 2 weeks | Park64
Barthel Index (BI) | Self report, observation/performance proxy | 10 | Activity51 | Yes | Yes | Yes | NR | 2–52 weeks | Askim143 Wayne158 GAPS Group148 Hafsteinsdottir149 Park64 Wayne158 Ryan156 Kalra151 Leeds153 Lincoln154
Functional Independence Measure (FIM) | Interview, proxy | 2 | Activity51 | Yes | Yes | Yes | NR | 24 weeks–6 months | Studenski157 Childers146
Fugl-Meyer Assessment | Observation/performance | 1 | Activity51 | Yes | Yes | Yes | NR | 12 weeks | Wayne158
Modified Rankin Scale (mRS) | Interview | 1 | Activity51 | Yes | Yes | Yes | NR | 52 weeks | Askim143
Motor Assessment Scale (MAS) | Performance | 1 | Activity51 | Yes | Yes | Yes | NR | 14 weeks | McClellan155
Nottingham Extended ADL | NR | 2 | Activity52 | Yes | Yes | NR | NR | 2 weeks–6 months | GAPS group153 Park64
EuroQoL: Quality of life for patient and carer | Self, interviewer, proxy | 5 | Activity16 | Yes | Yes | Yes | NR | 2 weeks–12 months | Kalra151 Ryan156 Lincoln154 GAPs Group153 Park64
5-point frequency of pain scale | NR | 1 | NR | NR | NR | NR | NR | 24 weeks | Childers146
5-point severity of pain scale | NR | 1 | NR | NR | NR | NR | NR | 24 weeks | Childers146
Admission/re-admission to hospitals | NR | 1 | NR | NR | NR | NR | NR | 12 months | Kalra151
Brief Pain Inventory Question 12 (BPI12) | NR | 1 | NR | NR | NR | NR | NR | 52 weeks | Chae145
Brief Pain Inventory Question 23 (BPI23) | NR | 1 | NR | NR | NR | NR | NR | 52 weeks | Chae145
CAMCOG-R, part of the Cambridge Examination for Mental Disorders in the Elderly | NR | 1 | NR | NR | NR | NR | NR | 6 months | Leeds153
Caregiver Strain Index (CSI) | NR | 3 | NR | NR | NR | NR | NR | 6 months–52 weeks | Askim143 Fjaertof147 Lincoln154
COOP score | NR | 1 | NR | NR | NR | NR | NR | 4 weeks | Barreca144
EQ-VAS: (EuroQoL—Visual Analog Scale) | NR | 2 | NR | NR | NR | NR | NR | 2 weeks–3 months | Park64 Ryan156
Extended activities of daily living ADL | NR | 1 | NR | NR | NR | NR | NR | 6 months | Lincoln154
Functional Reach Test (FR) | NR | 1 | NR | NR | NR | NR | NR | 14 weeks | McClellan155
Gait speed thresholds for community ambulation | NR | 1 | NR | NR | NR | NR | NR | 6 months | Studenski157
General Health Questionnaire (GHQ) 12 | NR | 1 | NR | NR | NR | NR | NR | 6 months | Lincoln154
General Health Questionnaire (GHQ-12) | NR | 1 | NR | NR | NR | NR | NR | 6 months | Lincoln154
Global rating scale: | NR | 1 | NR | NR | NR | NR | NR | 4 weeks | Barreca144
HADS (Hospital Anxiety and Depression Scale) | NR | 2 | NR | NR | NR | NR | NR | 3–12 months | Kalra151 Ryan156
Health-related quality of life (HRQoL): | NR | 1 | NR | NR | NR | NR | NR | 6 months | Leeds153
Knowledge of stroke | NR | 1 | NR | NR | NR | NR | NR | 6 months | Lincoln154
Lawton & Brody instrumental ADL | NR | 1 | NR | NR | NR | NR | NR | 6 months | Studenski157
Length of initial hospital stay: | NR | 1 | NR | NR | NR | NR | NR | 52 weeks | Askim143
Length of total institutional stay: | NR | 1 | NR | NR | NR | NR | NR | 52 weeks | Askim143
Montgomery-Asberg Depression Scale | NR | 1 | NR | NR | NR | NR | NR | 52 weeks | Fjaertof147
Mortality or Institutionalization | NR | 1 | NR | NR | NR | NR | NR | 12 months | Kalra151
Patient-practitioner interactions | NR | 1 | NR | NR | NR | NR | NR | 12 weeks | Wayne158
Physiological core index (PCI) | NR | 1 | NR | NR | NR | NR | NR | 16 weeks | Johnson150
Satisfaction with care | NR | 1 | NR | NR | NR | NR | NR | 6 months | Lincoln154
Self-administered Treatment Credibility Scale | NR | 1 | NR | NR | NR | NR | NR | 12 weeks | Wayne158
Self-efficacy Scale | NR | 1 | NR | NR | NR | NR | NR | 12 months | Kendall152
Swallowing status | NR | 1 | NR | NR | NR | NR | NR | 2 weeks | Park64
UE range of motion (ROM) | NR | 1 | NR | NR | NR | NR | NR | 12 weeks | Wayne158
Visual analogue scale (VAS) | NR | 1 | NR | NR | NR | NR | NR | 52 weeks | Hafsteinsdottir149

Abbreviations: NR=Not reported

* Psychometric properties of outcomes measures established for use in stroke patients not specific domains of functions (e.g ambulation) (Refers to all tables in this Appendix).

** This report did not examine if a link existed between an instrument’s psychometric properties and mode administration (e.g self-report, proxy) (Refers to all tables in this Appendix).

Table D3 Outcome measurement instruments used Daily Activity studies^*^

Outcome | Mode of Administration^**^ | Frequency in studies | ICF domain | Reliability in Stroke | Validity in Stroke | Tested for Responsiveness | MCID in stroke | Range of follow up time for studies | Study Author
Canadian Occupational Performance Measure (COPM) | Interview | 1 | Participation51 | Yes | Yes | Yes | NR | NR | Gilmore73
Nottingham Extended Activities of Daily Living (NEADL) | NR | 1 | Participation52 | Yes | Yes | Yes | NR | 7 months | Mead165
Fugl-Meyer Assessment of Motor Recovery (FM) | Observation/performance | 7 | Function44,51 | Yes | Yes | NR | NR | 1 week–6 months | Boake159 Daly160 Hsieh164 Page168 Wu175 Gladstone162 Yagura176
Wolf Motor Function Test (WMFT) | NR | 2 | Activity9 | Yes | Yes | Yes | NR | 6–12 months | Wittenberg173 Wolf174
Older Americans Resources and Services Scale | NR | 1 | Activity9 | Yes | NR | NR | NR | 6 weeks | Higgins163
CMSA Disability Inventory | NR | 1 | Activity9,16 | Yes | Yes | Yes | NR | 3 months | Gladstone162
Rivermead Mobility Index (RMI) | NR | 3 | Activity16 | Yes | Yes | Yes | NR | 12 weeks–6 months | Pohl169 Sackley171 Van Nes172
Barthel Index | Self report, observation/performance proxy | 4 | Activity44,51,52 | Yes | Yes | Yes | NR | 6 weeks–12 months | Pohl169 (primary) Sackley171 Langhammer71 Van Nes172 Higgins163
Functional Independence Measure (FIM) | Interview, proxy | 6 | Activity51 | Yes | Yes | NR | NR | 3 weeks–7 months | Rydwik170 Hsieh164 Mead165 Wu175 Gladstone162 Yagura176
Berg Balance Scale | Performance | 1 | Activity51 | Yes | Yes | Yes | NR | 12 weeks | Van Nes172
Clinical Outcome Variable Score (COVS) | Observation/performance | 1 | Activity51 | Yes | Yes | Yes | NR | 3 months | Gladstone162
Nine-Hole Peg Test | Performance | 1 | Activity51 | Yes | Yes | Yes | NR | 6 weeks | Higgins163
Timed up and go (TUG) | Performance | 1 | Activity51 | Yes | Yes | Yes | NR | 7 months | Mead165
Action Research Arm Test (ARA) | Observation/performance | 1 | Activity51 | Yes | Yes | Yes | NR | 1 week | Page168
CMSA arm and hand for Upper Limb Function | NR | 1 | Activity9 | Yes | Yes | Yes | NR | 3 months | Gladstone162
Motor Activity Log (MAL) | NR | 3 | NR | NR | NR | NR | NR | 3 weeks–12 months | Wu175 Wolf174 Wittenberg173 Boake159
Arm Motor Ability Test (AMAT) | NR | 1 | NR | NR | NR | NR | NR | 6 months | Daly160
Box and Block Test | NR | 1 | NR | NR | NR | NR | NR | 6 weeks | Higgins163
Elderly Mobility Scale (EMS) | NR | 1 | NR | NR | NR | NR | NR | 7 months | Mead165
Functional Reach | NR | 1 | NR | NR | NR | NR | NR | 7 months | Mead165
Instrumental ADL | NR | 1 | NR | NR | NR | NR | NR | 6 months | Ertel161
Klein Bell Activities of Daily Living Scale (KB-ADL) | NR | 1 | NR | NR | NR | NR | NR | NR | Gilmore73
Physical Performance Test | NR | 1 | NR | NR | NR | NR | NR | 6 months | Ertel161
Sit to Stand | NR | 1 | NR | NR | NR | NR | NR | 7 months | Mead165
Test d’Evaluation des Membres superieurs des Personnes Agees (TEMPA) | NR | 1 | NR | NR | NR | NR | NR | 6 weeks | Higgins163

Abbreviations: ADL=Activities of Daily Living; AMAT=Arm Motor Ability Test; ARA=Action Research Arm Test; CMSA=Chedoke McMaster Stroke Assessment; COPM=Canadian Occupational Performance Measure; COVS=Clinical Outcome Variable Score; EMS=Elderly Mobility Scale; FIM=Functional Independence Measure; FM=Fugl-Meyer Assessment of Motor Recovery; KB-ADL; Klein Bell Activities of Daily Living Scale; MAL=Motor Activity Log; NEADL=Nottingham Extended Activities of Daily Living; RMI=Rivermead Mobility Index; TEMPA=Test d’Evaluation des Membres superieurs des Personnes Agees; TUG=Timed up and go; WMFT=Wolf Motor Function Test.

* Psychometric properties of outcomes measures established for use in stroke patients not specific domains of functions (e.g ambulation) (Refers to all tables in this Appendix).

** This report did not examine if a link existed between an instrument’s psychometric properties and mode administration (e.g self-report, proxy) (Refers to all tables in this Appendix).

Table D4 Outcome measurement instruments used in Cognition studies^*^

Outcome | Mode of Administration^**^ | Frequency in studies | ICF domain | Reliability in Stroke | Validity in Stroke | Tested for Responsiveness | MCID in stroke | Range of follow up time for studies | Study Author
Barthel Index (BI) | Self report, observation/performance, proxy | 5 | Activity44,51,52 | Yes | Yes | Yes | NR | 1.5–24 months | Harvey180 McKinney183 Nys184 Pyoria187 Robertson188
Motricity Index | NR | 2 | Function52 | Yes | Yes | Yes | NR | 7 weeks–24 months | Frassinetti179 Robertson188
Behavioral Inattention Test (BIT) | NR | 4 | NR | NR | NR | NR | NR | 7 weeks–24 months/20 sessions | Cherney76 Frassinetti179 Harvey180 Robertson188
Accuracy was calculated as a function of test and session | NR | 1 | NR | NR | NR | NR | NR | NR | Zeloni192
Adaptation effect | NR | 1 | NR | NR | NR | NR | NR | 7 weeks | Frassinetti179
After effect | NR | 1 | NR | NR | NR | NR | NR | 7 weeks | Frassinetti179
Cancellation tests | NR | 1 | NR | NR | NR | NR | NR | 7 weeks | Frassinetti179
Cognitive Failures Questionnaires (CFQ) | NR | 1 | NR | NR | NR | NR | NR | 6 months | McKinney183
Cognitive functioning | NR | 1 | NR | NR | NR | NR | NR | 12 months | Rorsman190
Cognitively intact | NR | 1 | NR | NR | NR | NR | NR | 6–10 months | Nys184
Duration of the after-effect | NR | 1 | NR | NR | NR | NR | NR | 7 weeks | Frassinetti179
Elevator and lottery sub-tests of the TEA (test of everyday attention) | NR | 1 | NR | NR | NR | NR | NR | 1.5 months | Harvey180
Fluff test | NR | 1 | NR | NR | NR | NR | NR | 7 weeks | Frassinetti179
Frenchay Arm Test | NR | 1 | NR | NR | NR | NR | NR | 24 months | Robertson188
Kinematic | NR | 1 | NR | NR | NR | NR | NR | 6 weeks | Cirstea177
Kinesthetic and visual imagery questionnaire ( a modified version of the movement imagery questionnaire) | NR | 1 | NR | NR | NR | NR | NR | 2 days | Malouin182
Laterality bias from the Balloons test | NR | 1 | NR | NR | NR | NR | NR | 1.5 months | Harvey180
Motor imagery screening test | NR | 1 | NR | NR | NR | NR | NR | 2 days | Malouin182
Motor performance | NR | 1 | NR | NR | NR | NR | NR | 2 days | Malouin182
Neuropsychological tests | NR | 1 | NR | NR | NR | NR | NR | 5 weeks | Westerberg75
Pointing task | NR | 1 | NR | NR | NR | NR | NR | 7 weeks | Frassinetti179
Progress through a self-medication program) | NR | 1 | NR | NR | NR | NR | NR | Varied | Purdy186
Reading test | NR | 1 | NR | NR | NR | NR | NR | 7 weeks | Frassinetti179
Rivermead Perceptual Assessment Battery (RPAB) | NR | 1 | NR | NR | NR | NR | NR | 6 weeks | Edmans178
Room description and objects reaching tests: | NR | 1 | NR | NR | NR | NR | NR | 7 weeks | Frassinetti179
Self-rating on cognitive functioning in daily life (CFQ) | NR | 1 | NR | NR | NR | NR | NR | 5 weeks | Westerberg75
Severity of cognitive impairment | NR | 1 | NR | NR | NR | NR | NR | 6–10 months | Nys184
Stimuli detected in lower left visual field | NR | 1 | NR | NR | NR | NR | NR | 24 months | Robertson188
Stimuli detected in upper left visual field | NR | 1 | NR | NR | NR | NR | NR | 24 months | Robertson188
Stroop Neuropsychological screening Test (SNST) | NR | 1 | NR | NR | NR | NR | NR | 20 sessions | Cherney76
Tactile Sensory Detections | NR | 1 | NR | NR | NR | NR | NR | 24 months | Robertson188
Test of everyday attention-elevator counting | NR | 1 | NR | NR | NR | NR | NR | 24 months | Robertson188
Patient and carer neglect rating scores | NR | 1 | NR | NR | NR | NR | NR | 1.5 months | Harvey180
Verbal memory-immediate recall | NR | 1 | NR | NR | NR | NR | NR | 24 months | Robertson188
Working memory | NR | 1 | NR | NR | NR | NR | NR | 2 days | Malouin182
Behavioral Inattention Tests (BIT) behavioral scores | NR | 1 | NR | NR | NR | NR | NR | 1.5 months | Harvey180
Behavioral Inattention Tests (BIT) conventional scores | NR | 1 | NR | NR | NR | NR | NR | 1.5 months | Harvey180
Mini-Mental State Examination (MMSE) | Observation/performance | 5 | Function71 | No | No | No | NR | 3–12 weeks/20 sessions | Cherney76 Kimura181 Tang191 Ozdemir185 Robinson190

Abbreviations: NR=Not reported

* Psychometric properties of outcomes measures established for use in stroke patients not specific domains of functions (e.g ambulation) (Refers to all tables in this Appendix).

** This report did not examine if a link existed between an instrument’s psychometric properties and mode administration (e.g self-report, proxy) (Refers to all tables in this Appendix).

Table D5 Outcome measurement instruments used in Communication studies^*^

Outcome | Mode of Administration^**^ | Frequency in studies | ICF domain | Reliability in Stroke | Validity in Stroke | Tested for Responsiveness | MCID in stroke | Range of follow up time for studies | Study Author
Amsterdam Nijmegen Everyday Language Test (ANLET) | NR | 2 | NR | NR | NR | NR | NR | 7–12 months | Doesborgh196 Laska198
Aphasia Quotient of Western Aphasia Battery (WAB) | NR | 1 | NR | NR | NR | NR | NR | 20 weeks | Berthier195
Caplans and Hanna Sentence Production Test | NR | 1 | NR | NR | NR | NR | NR | 7 months | Rochon81
Communicative Activity Log (CAL) | NR | 1 | NR | NR | NR | NR | NR | 20 weeks | Berthier195
Constructional Apraxia | NR | 1 | NR | NR | NR | NR | NR | 18 weeks | Smania200
Dysarthria | NR | 1 | NR | NR | NR | NR | NR | 1 years | Wolfe202
Dysphagia | NR | 1 | NR | NR | NR | NR | NR | 1 year | Wolfe202
Frenchay Aphasia Screening Test (FAST) | NR | 1 | NR | NR | NR | NR | NR | 1 year | Wolfe202
Gesture Comprehension Tests | NR | 1 | NR | NR | NR | NR | NR | 18 weeks | Smania200
Language assessment: (standardized Persian language test) | NR | 1 | NR | NR | NR | NR | NR | 4 months | Ashtary193
Narrative Production Task | NR | 1 | NR | NR | NR | NR | NR | 7 months | Rochon81
Neuropsychological Test Battery | NR | 1 | NR | NR | NR | NR | NR | 6 weeks | Kessler197
Oral apraxia | NR | 1 | NR | NR | NR | NR | NR | 18 weeks | Smania200
Picture Description with Structure Modeling (PDSM) | NR | 1 | NR | NR | NR | NR | NR | 7 months | Rochon81
Phonological measures | NR | 1 | NR | NR | NR | NR | NR | 7 months | Doesborgh196
Porch Index of Communicative Ability (PICA) | NR | 1 | NR | NR | NR | NR | NR | 6 months | Walker-Batson201
Picture comprehension test | NR | 1 | NR | NR | NR | NR | NR | 7 months | Rochon81
Reinvang’s aphasia tests | NR | 1 | NR | NR | NR | NR | NR | 12 months | Laska198
Semantic Association Test | NR | 1 | NR | NR | NR | NR | NR | 7 months | Doesborgh196
Philadelphia Comprehension Battery (PCB) | NR | 1 | NR | NR | NR | NR | NR | 7 months | Rochon81
Speech disturbance | NR | 1 | NR | NR | NR | NR | NR | 1 year | Wolfe202
Standard Aphasia tests | NR | 1 | NR | NR | NR | NR | NR | 4 weeks | Pulvermuller199
Psycholinguistic Assessment of Language Processing in Aphasia (PALPA) | NR | 1 | NR | NR | NR | NR | NR | 20 weeks | Berthier195
Verbal comprehension | NR | 1 | NR | NR | NR | NR | NR | 18 weeks | Smania200
Western Aphasia Battery (WAB) | NR | 1 | NR | NR | NR | NR | NR | 24 weeks | Bakheit194

Abbreviations: NR=Not reported

* Psychometric properties of outcomes measures established for use in stroke patients not specific domains of functions (e.g ambulation) (Refers to all tables in this Appendix).

** This report did not examine if a link existed between an instrument’s psychometric properties and mode administration (e.g self-report, proxy) (Refers to all tables in this Appendix).

Table D6 Outcome measurement instruments used in Dysphagia studies^*^

Outcome | Mode of Administration^**^ | Frequency in studies | ICF domain | Reliability in Stroke | Validity in Stroke | Tested for Responsiveness | MCID in stroke | Range of follow up time for studies | Study Author
Aspiration Penetration Scale | NR | 1 | NR | NR | NR | NR | NR | None | Power210
Coughing/choking frequency during meal | NR | 1 | NR | NR | NR | NR | NR | 8 weeks | Lin2
Cricopharyngeal Opening Duration | NR | 1 | NR | NR | NR | NR | NR | None | Power210
Efficacy of swallowing (volume per second, volume per swallow) | NR | 1 | NR | NR | NR | NR | NR | 8 weeks | Lin2
Functional Oral Intake Scale (FO1S) | NR | 1 | NR | NR | NR | NR | NR | NR | Crary204
Functional swallowing | NR | 1 | NR | NR | NR | NR | NR | 6 months | Carnaby203
Incidence of aspiration pneumonia | NR | 1 | NR | NR | NR | NR | NR | NR | Huang84
Laryngeal Closure Duration | NR | 1 | NR | NR | NR | NR | NR | None | Power210
Latency of swallowing reflex (seconds) | NR | 1 | NR | NR | NR | NR | NR | 30 days | Ebihara206
Neurological examination | NR | 1 | NR | NR | NR | NR | NR | 8 weeks | Lin2
Normal diet | NR | 1 | NR | NR | NR | NR | NR | 6 months | Carnaby203
Number of swallows for 1 minute | NR | 1 | NR | NR | NR | NR | NR | 30 days | Ebihara206
Oral Transit Time | NR | 1 | NR | NR | NR | NR | NR | None | Power210
Pharyngeal retention | NR | 1 | NR | NR | NR | NR | NR | 4 weeks | Seki211
Pharyngeal Transit Time | NR | 1 | NR | NR | NR | NR | NR | NR | Power210
Pulmonary aspiration | NR | 1 | NR | NR | NR | NR | NR | 7 days | Goulding83
Signs and/or symptoms on a swallowing questionnaire | NR | 1 | NR | NR | NR | NR | NR | 8 weeks | Lin2
Swallow Response Time | NR | 1 | NR | NR | NR | NR | NR | None | Power210
Swallowing time of water and fluid | NR | 1 | NR | NR | NR | NR | NR | 4 weeks | Seki211
Tracheobronchial post deglutitive aspiration | NR | 1 | NR | NR | NR | NR | NR | 4 weeks | Seki211

Abbreviations: NR=Not reported

* Psychometric properties of outcomes measures established for use in stroke patients not specific domains of functions (e.g ambulation) (Refers to all tables in this Appendix)

** This report did not examine if a link existed between an instrument’s psychometric properties and mode administration (e.g self-report, proxy) (Refers to all tables in this Appendix)