# Quality Tables

Table C1a Quality measures of randomized controlled trials with Ambulation outcomes

Study | Study reported as Randomized | Randomized Process Described | Concealment of randomization | “Blinding” as described by author | Patients blinded | Healthcare provider Blinded | Data Collector Blinded | Outcome assessor blinded | Reasons and No. of Dropouts and Withdrawals Reported | Reporting adverse events | Authors report co-morbidity | Authors report co-intervention | Consistency of the therapy in the groups (was it applied to all patients)
Askim125 2006 Norway | Yes | Yes | Yes | Yes | No | No | No | Yes | Yes | No | Yes | No | Yes
Bayouk126 2006 Canada | Yes | No | NR | NR | NR | NR | NR | NR | Yes | No | No | No | Yes
Bayram127 2006 Turkey | Yes | No | NR | Yes | NR | NR | NR | Yes | Yes | No | Yes | No | Yes
Chen128 2005 Taiwan | Yes | No | NR | Yes | NR | NR | NR | NR | No | No | No | Yes | Yes
Macko130 2005 United States | Yes | Yes | NR | Yes | No | No | Yes | Yes | Yes | Yes | Yes | No | Yes
Marigold60 2005 Canada | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes
Mayr131 2007 United States | Yes | Yes | NR | Yes | No | No | NR | Yes | Yes | No | Yes | Yes | Yes
Pang132 2005 Canada | Yes | Yes | Yes | Yes | No | No | Yes | Yes | Yes | Yes | Yes | No | Yes
Peurala133 2005 Finland | Yes | No | Yes | NR | NR | NR | NR | NR | Yes | No | Yes | No | Yes
Sutbeyaz135 2007 Turkey | Yes | Yes | Yes | Yes | No | No | Yes | Yes | Yes | No | No | No | Yes
Sze136 2002 Hong Kong | Yes | Yes | Yes | Yes | No | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Thaut137 2007 United States | Yes | Yes | Yes | Yes | No | No | NR | Yes | Yes | No | No | No | Yes
Tong138 2006 China | Yes | Yes | Yes | No | No | No | No | No | Yes | Yes | No | No | Yes
Yan139 2005 China | Yes | Yes | Yes | Yes | No | No | NR | Yes | Yes | Yes | Yes | No | Yes
Yang140 2007 Taiwan | Yes | Yes | Yes | Yes | No | No | NR | Yes | Yes | No | Yes | No | Yes
Yavuzer141 2006 Turkey | Yes | Yes | NR | Yes | No | No | Yes | Yes | Yes | No | Yes | No | Yes
Yavuzer142 2006 Turkey | Yes | Yes | Yes | Yes | No | No | NR | Yes | Yes | No | No | No | Yes

Abbreviations: NR—not reported

Table C1b Quality measures of other comparative clinical trials with Ambulation outcomes

Study | Study groups comparable at baseline for important confounders | Were all study subjects drawn from the same source population? (answer ‘no’ for historical controls) | “Blinding” as described by author | Patients blinded | Healthcare provider Blinded | Data Collector Blinded | Outcome assessor blinded | Reasons and No. of Dropouts and Withdrawals Reported [ # enrolled/number completing] | Reporting adverse events | Authors report co-morbidity | Authors report co-intervention | Consistency of the therapy in the groups (was it applied to all patients)
English129 2007 Australia | No | Yes | Yes | No | No | NR | Yes | Yes | Yes | Yes | No | Yes
Peurala134 2005 Finland | Yes | Yes | No | No | No | No | No | No | No | No | No | Yes
Roerdink63 2007 Netherlands | No | No | No | No | No | No | No | No | No | Yes | No | Yes

Abbreviations: NR = not reported

Table C2a Quality measures of randomized controlled trials with Quality of Life outcomes

Study | Study reported as Randomized | Randomized Process Described | Concealment of randomization | “Blinding” as described by author | Patients blinded | Healthcare provider Blinded | Data Collector Blinded | Outcome assessor blinded | Reasons and No. of Dropouts and Withdrawals Reported | Reporting adverse events | Authors report co-morbidity | Authors report co-intervention | Consistency of the therapy in the groups (was it applied to all patients)
Askim125 2006 Norway | Yes | Yes | Yes | Yes | No | No | No | Yes | Yes | No | Yes | No | Yes
Barreca144 2004 Canada | Yes | Yes | No | Yes | No | No | NR | Yes | No | No | No | No | Yes
Chae145 2005 USA | Yes | Yes | NR | Yes | No | No | No | Yes | No | Yes | Yes | Yes | Yes
Childers146 2004 USA | Yes | No | Yes | Yes | Yes | Yes | NR | Yes | Yes | Yes | Yes | Yes | Yes
Fjaertoft147 2004 Norway | Yes | Yes | NR | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | No | Yes
GAPS Group148 2004 Glasgow | Yes | Yes | Yes | Yes | NR | NR | NR | Yes | Yes | Yes | Yes | No | Yes
Johnson150 2004 United Kingdom | Yes | Yes | NR | Yes | No | No | No | No | Yes | No | No | Yes | Yes
Kalra151 2005 UK | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Kendall152 2007 Australia | Yes | Yes | NR | No | NR | NR | NR | NR | Yes | No | Yes | No | Yes
Lincoln154 2004 United Kingdom | Yes | Yes | NR | Yes | No | No | NR | Yes | Yes | No | No | No | Yes
McClellan155 2004 Australia | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | No | Yes
Park64 2005 UK | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes
Ryan156 2006 UK | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | No | Yes
Studenski157 2005 USA | Yes | No | NR | Yes | No | No | Yes | Yes | Yes | No | Yes | No | Yes
Wayne158 2005 USA | Yes | Yes | Yes | Yes | Yes | No | Yes | NR | Yes | No | Yes | No | Yes

Abbreviations: NR = not reported

Table C2b Quality measures of other comparative clinical trials with Quality of Life outcomes

Study | Study groups comparable at baseline for important confounders | Were all study subjects drawn from the same source population? (answer ‘no’ for historical controls) | “Blinding” as described by author | Patients blinded | Healthcare provider Blinded | Data Collector Blinded | Outcome assessor blinded | Reasons and No. of Dropouts and Withdrawals Reported | Reporting adverse events | Authors report co-morbidity | Authors report co-intervention | Consistency of the therapy in the groups (was it applied to all patients)
Leeds153 2004 UK | Yes | Yes | Yes | No | No | No | No | Yes | No | Yes | No | Yes
Hafsteindottir149 2005 The Netherlands | Yes | Yes | No | NR | NR | NR | NR | Yes | No | Yes | No | Yes

Abbreviations: NR = not reported

Table C3 Quality measures of randomized controlled trials with Daily Activities outcomes

Study | Study reported as Randomized | Randomized Process Described | Concealment of randomization | “Blinding” as described by author | Patients blinded | Healthcare provider Blinded | Data Collector Blinded | Outcome assessor blinded | Reasons and No. of Dropouts and Withdrawals Reported | Reporting adverse events | Authors report co-morbidity | Authors report co-intervention | Consistency of the therapy in the groups (was it applied to all patients)
Boake159 2007 United States | Yes | No | NR | Yes | NR | NR | NR | Yes | Yes | Yes | No | No | Yes
Daly160 2005 United States | Yes | No | NR | Yes | No | No | Yes | Yes | Yes | Yes | No | No | Yes
Ertel161 2007 United States | Yes | Yes | No | Yes | No | No | Yes | Yes | Yes | No | Yes | No | Yes
Gilmore73 2007 Canada | Yes | Yes | NR | No | NR | NR | NR | NR | No | No | No | No | Yes
Gladstone162 2006 Canada | Yes | Yes | NR | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Higgins163 2006 Canada | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes
Hsieh164 2007 Taiwan | Yes | Yes | Yes | Yes | No | No | Yes | Yes | Yes | No | Yes | Yes | Yes
Langhammer73 2007 Norway | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | No | Yes
Mead165 2007 United Kingdom | Yes | Yes | Yes | Yes | Yes | NR | NR | Yes | Yes | Yes | Yes | No | Yes
Ng166 2007 Hong Kong | Yes | Yes | NR | Yes | No | No | Yes | Yes | Yes | No | Yes | No | Yes
Olney167 2006 Canada | Yes | Yes | Yes | Yes | NR | NR | NR | No | Yes | No | No | No | Yes
Page168 2007 United States | Yes | Yes | Yes | Yes | NR | NR | NR | Yes | Yes | No | Yes | No | Yes
Pohl169 2007 Germany | Yes | Yes | Yes | Yes | No | Yes | NR | Yes | Yes | Yes | Yes | No | Yes
Rydwik170 2006 Sweden | Yes | Yes | NR | Yes | No | No | NR | Yes | Yes | No | No | No | Yes
Sackley171 2006 United Kingdom | Yes | Yes | Yes | Yes | NR | No | NR | Yes | Yes | Yes | No | No | Yes
van Nes172 2006 Netherlands | Yes | Yes | Yes | Yes | Yes | NR | Yes | Yes | Yes | Yes | Yes | No | Yes
Wittenberg173 2003 United States | Yes | Yes | NR | Yes | NR | NR | NR | Yes | Yes | No | No | No | No
Wolf174 2006 United States | Yes | Yes | NR | Yes | No | No | Yes | Yes | Yes | Yes | Yes | No | No
Wu175 2007 Taiwan | Yes | Yes | NR | Yes | Yes | NR | Yes | NR | Yes | No | No | No | Yes
Yagura176 2006 Japan | Yes | Yes | Yes | Yes | No | NR | NR | No | Yes. | Yes | Yes | No | Yes

Abbreviations: NR = not reported

Table C4a Quality measures of randomized controlled trials with Cognition outcomes

Study | Study reported as Randomized | Randomized Process Described | Concealment of randomization | Author described blinding | Patients blinded | Healthcare provider Blinded | Data Collector Blinded | Outcome assessor blinded | Reasons and No. of Dropouts and Withdrawals Reported | Reporting adverse events | Authors report co-morbidity | Authors report co-intervention | Consistency of the therapy in the groups (was it applied to all patients)
Cherney76 2003 USA | Yes | No | NR | No | NR | NR | NR | NR | Yes | No | No | No | Yes
Cirstea177 2006 Canada | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | No | Yes
Edmans178 2000 UK | Yes | Yes | Yes | Yes | No | No | NR | Yes | Yes | No | Yes | No | Yes
Frassinetti179 2002 Italy | Yes | Yes | NR | No | No | No | No | No | Yes | No | Yes | No | Yes
Harvey180 2003 UK | Yes | Yes | NR | NR | NR | NR | NR | NR | Yes | No | Yes | No | Yes
Kimura181 2000 USA | Yes | No | NR | Yes | Yes | Yes | NR | Yes | Yes | No | Yes | No | Yes
Malouin182 2004 Canada | Yes | No | NR | No | No | No | NR | NR | Yes | No | Yes | Yes | Yes
McKinney183 2002 UK | Yes | Yes | Yes | Yes | No | NR | Yes | Yes | Yes | No | Yes | Yes | Yes
Ozdemir185 2001 Turkey | Yes | Yes | NR | NR | No | No | NR | NR | No | Yes | Yes | Yes | No
Robertson188 2002 UK | Yes | No | NR | Yes | Yes | No | Yes | NR | Yes | No | Yes | No | Yes
Robinson189 2000 USA | Yes | No | NR | Yes | Yes | NR | NR | Yes | Yes | Yes | Yes | Yes | Yes
Rorsman190 2006 Sweden | Yes | No | Yes | NR | No | No | Yes | Yes | Yes | Yes | Yes | Yes | No
Tang191 2005 China | Yes | Yes | NR | Yes | No | No | No | Yes | No | No | Yes | No | NR
Westerberg75 2007 Stockholm | Yes | No | No | No | NR | NR | NR | NR | No | No | Yes | No | No
Zeloni192 2002 Italy | Phase 1: Yes Phase 2: No | No | No | No | No | No | NR | NR | Yes | No | No | No | Yes

Abbreviations: NR = not reported

Table C4b Quality measures of other comparative clinical trials with Cognition outcomes

Study | Study groups comparable at baseline for important confounders | Were all study subjects drawn from the same source population? | Author described blinding | Patients blinded | Healthcare provider Blinded | Data Collector Blinded | Outcome assessor blinded | Reasons and No. of Dropouts and Withdrawals Reported | Reporting adverse events | Authors report co-morbidity | Authors report co-intervention | Consistency of the therapy in the groups (was it applied to all patients)
Nys184 2006 Netherlands | Yes | Yes | NR | NR | NR | NR | NR | No | Yes | Yes | No | No
Purdy186 2007 USA | No | Yes | No | No | No | No | No | No | No | Yes | No | Yes
Pyoria187 2007 Finland | No | Yes | No | No | No | No | No | Yes | No | Yes | No | No

Abbreviations: NR = not reported

Table C5 Quality measures of randomized controlled trials with Communication outcomes

Study | Study reported as Randomized | Randomized Process Described | Concealment of randomization | Author described blinding | Patients blinded | Healthcare provider Blinded | Data Collector Blinded | Outcome assessor blinded | Reasons and No. of Dropouts and Withdrawals Reported | Reporting adverse events | Authors report co-morbidity | Authors report co-intervention | Consistency of the therapy in the groups (was it applied to all patients)
Ashtary193 2006 Iran | Yes | Yes | NR | Yes | Yes | NR | Yes | Yes | Yes | Yes | Yes | No | Yes
Bakheit194 2007 UK | Yes | Yes | Yes | Yes | NR | NR | NR | Yes | Yes | No | Yes | No | Yes
Berthier195 2006 Spain | Yes | Yes | Yes | Yes | Yes | Yes | NR | NR | Yes | Yes | No | Yes | Yes
Doesborgh196 2004 Netherlands | Yes | Yes | Yes | Yes | NR | NR | Yes | Yes | Yes | No | Yes | No | Yes
Kessler197 2000 Germany | Yes | Yes | NR | Yes | NR | NR | NR | NR | No | No | Yes | Yes | Yes
Laska198 2005 Sweden | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No
Pulvermuller199 2001 UK | Yes | Yes | NR | Yes | NR | NR | NR | Yes | No | No | No | No | No
Rochon81 2005 Canada | Yes | No | NR | No | NR | NR | NR | NR | No | No | No | No | Yes
Smania200 2006 Italy | Yes | No | NR | Yes | NR | NR | NR | Yes | Yes | No | Yes | No | Yes
Thorsen79 2005 Sweden | Yes | Yes | Yes | Yes | NR | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes
Walker-Batson201 2001 USA | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Wolfe202 2000 UK | Yes | Yes | Yes | Yes | No | NR | NR | Yes | Yes | No | No | No | Yes

Abbreviations: NR = not reported

Table C6a Quality measures of randomized controlled trials with Dysphagia outcomes

Study | Study reported as Randomized | Randomized Process Described | Concealment of randomization | Author described blinding | Patients blinded | Healthcare provider Blinded | Data Collector Blinded | Outcome assessor blinded | Reasons and No. of Dropouts and Withdrawals Reported | Reporting adverse events | Authors report co-morbidity | Authors report co-intervention | Consistency of the therapy in the groups (was it applied to all patients)
Carnaby203 2006 United States | Yes | Yes | Yes | Yes | No | No | NR | Yes | Yes | Yes | Yes | No | No
Dennis205 2005 United Kingdom | Yes | Yes | Yes | Yes | No | No | NR | Yes | Yes | Yes | No | No | Yes
Study A
Dennis205 2005 United Kingdom | Yes | Yes | Yes | Yes | No | No | NR | Yes | Yes | Yes | No | No | Yes
Study B
Ebihara206 2006 Japan | Yes | Yes | NR | Yes | NR | NR | NR | Yes | Yes | No | Yes | No | Yes
Goulding83 2000 United Kingdom | Yes | Yes | NR | Yes | NR | NR | NR | Yes | Yes | Yes | Yes | No | No
Hamidon208 2006 Malaysia | Yes | Yes | NR | No | NR | NR | NR | NR | Yes | Yes | No | No | Yes
Power210 2006 United Kingdom | Yes | No | NR | Yes | NR | NR | NR | NR | Yes | No | No | No | Yes
Seki211 2005 Japan | Yes | No | NR | Yes | NR | NR | NR | Yes | Yes | Yes | No | No | Yes

Abbreviations: NR = not reported

Table C6b Quality measures of other comparative clinical trials with Dysphagia outcomes

Study | Study groups comparable at baseline for important confounders | Were all study subjects drawn from the same source population? (answer ‘no’ for historical controls) | “Blinding” as described by author | Patients blinded | Healthcare provider Blinded | Data Collector Blinded | Outcome assessor blinded | Reasons and No. of Dropouts and Withdrawals Reported | Reporting adverse events | Authors report co-morbidity | Authors report co-intervention | Consistency of the therapy in the groups (was it applied to all patients)
Crary204 2004 United States | No | No | No | NR | NR | NR | NR | Yes | No | No | No | Yes
Freed207 2001 United States | Yes | Yes | No | NR | NR | NR | NR | Yes | Yes | Yes | No | Yes
Huang84 2006 China | Yes | Yes | No | NR | NR | NR | NR | No | Yes | No | No | Yes
Iizuka209 2005 United States | Yes | Yes | No | NR | NR | NR | NR | No | Yes | No | No | Yes
Lin2 2003 Taiwan | Yes | Yes | No | NR | NR | NR | NR | Yes | No | No | No | Yes

Abbreviations: NR = not reported