# Demographic Tables

Table B1 Study, population and intervention characteristics for studies with Ambulation outcomes

Table B2 Study, population and Intervention characteristics for studies with Quality of Life outcomes

Table B3 Study, population and intervention characteristics for studies with Daily Activities outcomes

Table B4 Study, population and intervention characteristics for studies with Cognition outcomes

Table B5 Study, population and Intervention characteristics for studies with Communication outcomes

Table B6 Study, population and Intervention characteristics for studies with Dysphagia outcomes