# Detailed Search Strategies

## Cognition

### Cognition CINAHL

1. (letter or editorial or comment).pt.
2. cerebral vascular accident/
3. Rehabilitation, Cognitive/
4. 2 and 3
5. Cognition/
6. exp Cognition Disorders/
7. Dementia, Multi-Infarct/
8. (cognition or cognitive).ti.
9. or/5–8
10. rehabilitation/
11. (rehabilitation or recovery).ti.
12. or/10–11
13. 2 and 9 and 12
14. 13 or 4
15. 14 not 1
16. limit 15 to english
17. limit 16 to yr=“2003 – 2007”
18. limit 16 to yr=“2000 – 2007”
19. *Cerebral Vascular Accident/rh [Rehabilitation]
20. *cerebral vascular accident/
21. exp *Rehabilitation/
22. 20 and 21
23. 19 or 22
24. (letter or editorial or comment).pt.
25. Cognition/
26. Rehabilitation, Cognitive/
27. exp Cognition Disorders/
28. (cognition or cognitive).ti.
29. or/25–28
30. 23 and 29
31. 30 not 24
32. limit 31 to english
33. limit 32 to yr=“2003 – 2007”
34. limit 33 to yr=“2000 – 2007”
35. 18 or 34
36. exp Cognition Disorders/rh, th [Rehabilitation, Therapy]
37. Cognitive Therapy/
38. Rehabilitation, Cognitive/
39. or/36–38
40. exp Cognition Disorders/
41. (cognition or cognitive).ti.
42. mental function.ti.
43. exp Cognition/
44. or/40–43
45. exp Rehabilitation/
46. (rehabilitation or recovery).ti,ab.
47. therapy.ti.
48. or/45–47
49. 44 and 48
50. Cerebral Vascular Accident/rh, th [Rehabilitation, Therapy]
51. 50 and 44
52. stroke.ti.
53. (stroke adj (volume or heat)).ti.
54. 52 not 53
55. Cerebral Vascular Accident/
56. or/54–55
57. 39 or 49
58. 57 and 56
59. 58 or 51
60. (letter or editorial or comment).pt.
61. 59 not 60
62. limit 61 to english
63. limit 62 to yr=“2000 – 2007”
64. 63 or 35

### Cognition Medline

1. Cognitive Therapy/
2. Cognition Disorders/rh [Rehabilitation]
3. (cognition or cognitive).ti.
4. Dementia, Multi-Infarct/
5. or/1–4
6. exp stroke/
7. “Recovery of Function”/
8. exp rehabilitation/
9. “Recovery of Function”/
10. (rehabilitation or recovery).ti,ab.
11. or/7–10
12. 5 and 6 and 11
13. animals/ not (humans/ and animals/)
14. 12 not 13
15. (letter or editorial or comment).pt.
16. 14 not 15
17. limit 16 to english language
18. limit 17 to yr=“2003 – 2008”
19. exp Cognition Disorders/rh, th [Rehabilitation, Therapy]
20. Cognitive Therapy/
21. or/19–20
22. Dementia, Multi-Infarct/
23. (cognition or cognitive).ti.
24. cognition disorders/ or auditory perceptual disorders/
25. 22 or 23 or 24
26. “Recovery of Function”/
27. exp rehabilitation/
28. (rehabilitation or recovery).ti,ab.
29. therapy.ti.
30. or/26–29
31. 25 and 30
32. 21 or 31
33. stroke.ti.
34. (stroke adj (volume or heat)).ti.
35. 33 not 34
36. exp stroke/
37. or/35–36
38. 32 and 37
39. animals/ not (humans/ and animals/)
40. 38 not 39
41. (letter or editorial or comment).pt.
42. 40 not 41
43. limit 42 to english language
44. limit 43 to yr=“2000 – 2008”
45. 44 or 18

### Cognition PsycINFO

1. cerebrovascular accidents/
2. exp neuropsychological rehabilitation/
3. and/1–2
4. limit 3 to human
5. limit 4 to english language
6. limit 5 to yr=“2003 – 2008”
7. limit 5 to yr=“2000 – 2008”
8. cognitive rehabilitation/ or exp neuropsychological rehabilitation/
9. cognitive therapy/
10. or/8–9
11. (cognition or cognitive).ti.
12. mental function.ti.
13. cognition/ or cognitive impairment/ or exp cognitive processes/
14. or/11–13
15. (rehabilitation or recovery).ti,ab.
16. therapy.ti.
17. rehabilitation/
18. or/15–17
19. 14 and 18
20. 10 or 19
21. stroke.ti.
22. (stroke adj (volume or heat)).ti.
23. 21 not 22
24. cerebrovascular accidents/
25. or/23–24
26. 20 and 25
27. limit 26 to human
28. limit 27 to english language
29. limit 28 to yr=“2000 – 2008”
30. 29 or 7

## Ambulation

### Ambulation_CINAHL

1. *Cerebral Vascular Accident/rh [Rehabilitation]
2. *cerebral vascular accident/
3. exp *Rehabilitation/
4. 2 and 3
5. 1 or 4
6. (letter or editorial or comment).pt.
7. Walking/
8. ambulation.tw.
9. Physical Mobility/
10. (walking or mobiltiy).ti.
11. or/7–10
12. 5 and 11
13. 12 not 6
14. limit 13 to english
15. limit 14 to yr=“2003 – 2007”

### Ambulation Medline

Database: Ovid MEDLINE(R) <1950 to January Week 1 2008>

Search Strategy:

1. exp *Stroke/rh [Rehabilitation]
2. exp *Stroke/
3. exp Rehabilitation/
4. 2 and 3
5. 1 or 4
6. walking/
7. (mobility or ambulation).ti.
8. exp Gait Disorders, Neurologic/
9. or/6–8
10. 5 and 9
11. Gait Disorders, Neurologic/rh [Rehabilitation]
12. 2 and 11
13. 10 or 12
14. animals/ not (humans/ and animals/)
15. 13 not 14
16. limit 15 to english language
17. limit 16 to yr=“2003 – 2008”

## Quality of Life

### QOL CINAHL

1. *Cerebral Vascular Accident/rh [Rehabilitation]
2. *cerebral vascular accident/
3. exp *Rehabilitation/
4. 2 and 3
5. 1 or 4
6. (letter or editorial or comment).pt.
7. exp “Quality of Life”/
8. quality of life.tw.
9. QOL.tw.
10. or/7–9
11. 5 and 10
12. 11 not 6
13. limit 12 to english
14. limit 13 to yr=“2003 – 2007”

### QOL Medline

1. exp *stroke/rh
2. exp *stroke/
3. exp rehabilitation/
4. or/2–3
5. 1 or 4
6. animals/ not (humans/ and animals/)
7. (letter or editorial or comment).pt.
8. “Quality of Life”/
9. quality of life.ti.
10. or/8–9
11. 5 and 10
12. 11 not 6
13. 12 not 7
14. limit 13 to english language
15. limit 14 to yr=“2003 – 2008”

## Daily Activities

### Daily Activities CINAHL

1. *Cerebral Vascular Accident/rh [Rehabilitation]
2. *cerebral vascular accident/
3. exp *Rehabilitation/
4. 2 and 3
5. 1 or 4
6. (letter or editorial or comment).pt.
7. “Activities of Daily Living”/
8. ((daily or routine) adj3 (activities or tasks)).tw.
9. or/7–8
10. 5 and 9
11. 10 not 6
12. limit 11 to english
13. limit 12 to yr=“2003 – 2007”

### Daily Activities Medline

1. exp *Stroke/rh [Rehabilitation]
2. exp *Stroke/
3. exp Rehabilitation/
4. 2 and 3
5. 1 or 4
6. “Activities of Daily Living”/
7. ((daily or routine) adj3 (activities or tasks)).tw.
8. or/6–7
9. 5 and 8
10. animals/ not (humans/ and animals/)
11. 9 not 10
12. (letter or editorial or comment).pt.
13. 11 not 12
14. limit 13 to english language
15. limit 14 to yr=“2003 – 2008”

## Communication

### Communication CINAHL

1. (letter or editorial or comment).pt.
2. exp “Rehabilitation, Speech and Language”/
3. ((speech or language) adj (therap$ or training)).tw.
4. or/2–3
5. Cerebral Vascular Accident/
6. 5 and 4
7. 6 not 1
8. limit 7 to english
9. limit 8 to yr=“2003 – 2007”
10. exp Aphasia/rh, th [Rehabilitation, Therapy]
11. exp “Rehabilitation, Speech and Language”/
12. exp Speech Disorders/rh, th [Rehabilitation, Therapy]
13. ((speech or language) adj2 (therap$ or training or rehabilitation or recovery)).tw.
14. or/10–13
15. exp Cerebral Vascular Accident/
16. stroke.ti.
17. (stroke adj (volume or heat)).ti.
18. 16 not 17
19. 15 or 18
20. 14 and 19
21. (letter or editorial or comment).pt.
22. 20 not 21
23. limit 22 to english
24. limit 23 to yr=“2000 – 2007”
25. 24 or 9

### Communication Medline

1. exp *stroke/
2. exp Aphasia/rh [Rehabilitation]
3. exp “rehabilitation of speech and language disorders”/
4. ((speech or language) adj2 (therap$ or training or rehabilitation or recovery)).tw.
5. or/2–4
6. 1 and 5
7. animals/ not (humans/ and animals/)
8. 6 not 7
9. (letter or editorial or comment).pt.
10. 8 not 9
11. limit 10 to english language
12. limit 11 to yr=“2003 – 2008”
13. exp Aphasia/rh, th [Rehabilitation, Therapy]
14. exp “rehabilitation of speech and language disorders”/
15. exp Speech Disorders/rh, th [Rehabilitation, Therapy]
16. ((speech or language) adj2 (therap$ or training or rehabilitation or recovery)).tw.
17. or/13–16
18. exp stroke/
19. stroke.ti.
20. (stroke adj (volume or heat)).ti.
21. 19 not 20
22. 18 or 21
23. 17 and 22
24. animals/ not (humans/ and animals/)
25. 23 not 24
26. (letter or editorial or comment).pt.
27. 25 not 26
28. limit 27 to english language
29. limit 28 to yr=“2000 – 2008”
30. 29 or 12

### Communication PsycINFO

1. animals/ not (humans/ and animals/)
2. (letter or editorial or comment).pt.
3. exp Cerebrovascular Accidents/
4. speech therapy/
5. ((speech or language) adj2 (therap$ or training or rehabilitation or recovery)).tw.
6. or/4–5
7. 3 and 6
8. 7 not 1
9. 8 not 2
10. limit 9 to english language
11. limit 10 to yr=“2003 – 2008”
12. exp communication disorders/
13. exp treatment/
14. and/12–13
15. speech therapy/
16. ((speech or language) adj2 (therap$ or training or rehabilitation or recovery)).tw.
17. or/14–16
18. stroke.ti.
19. (stroke adj (volume or heat)).ti.
20. 18 not 19
21. exp Cerebrovascular Accidents/
22. or/20–21
23. 17 and 22
24. limit 23 to english language
25. limit 24 to human
26. limit 25 to yr=“2000 – 2008”
27. 26 or 11

## Dysphagia

### Dysphagia CINAHL

1. Cerebral Vascular Accident/
2. stroke.ti.
3. or/1–2
4. Deglutition Disorders/
5. dysphagia.ti.
6. (swallowing adj3 disorder?).ti.
7. or/4–6
8. 3 and 7
9. (letter or comment or editorial).pt.
10. 8 not 9
11. limit 10 to english
12. limit 11 to yr=“2003 – 2007”

### Dysphagia Medline

1. Deglutition Disorders/
2. dysphagia.ti.
3. (swallowing adj3 disorder?).ti.
4. or/1–3
5. exp Stroke/
6. stroke.ti.
7. or/5–6
8. 4 and 7
9. (letter or comment or editorial).pt.
10. 8 not 9
11. animals/ not (animals/ and humans/)
12. 10 not 11
13. limit 12 to english language
14. limit 13 to yr=“2003 – 2008”

## Systematic Reviews

### Systematic Reviews CINAHL

1. exp Cerebrovascular Disorders/
2. (stroke$ or cerebrovascular$ or cerebral vascular or CVA$).tw.
3. ((cerebral or cerebellar or brainstem or vertebrobasilar) adj5 (infarct$ or isch?emi$ or thrombo$ or apoplexy or emboli$)).tw.
4. ((cerebral or intracerebral or intracranial or parenchymal or brain or intraventricular or brainstem or cerebellar or infratentorial or supratentorial or subarachnoid) adj (haemorrhage or hemorrhage or haematoma or hematoma or bleeding or aneurysm)).tw.
5. poststroke$.tw.
6. post-stroke.tw.
7. or/1–6
8. exp Rehabilitation/
9. exp Physical Therapy Modalities/
10. exp Therapy, Computer-Assisted/
11. exp Therapeutics/
12. (training or re-training or retraining or therap$ or rehabilitat$ or treatment$ or therapeutic$).tw.
13. or/8–12
14. 7 and 13
15. exp Cerebrovascular Disorders/rh [Rehabilitation]
16. or/14–15
17. animals/ not (animals/ and humans/)
18. 16 not 17
19. (letter or editorial or comment).pt.
20. 18 not 19
21. “Systematic Review”/
22. systematic review.pt.
23. systematic.tw.
24. (meta-analysis or metaanalysis).tw.
25. (cochrane adj2 review).tw.
26. or/21–25
27. 20 and 26
28. limit 27 to english
29. limit 28 to yr=“1990 – 2007”

### Systematic Reviews Medline

1. exp Cerebrovascular Disorders/
2. (stroke$ or cerebrovascular$ or cerebral vascular or CVA$).tw
3. ((cerebral or cerebellar or brainstem or vertebrobasilar) adj5 (infarct$ or isch?emi$ or thrombo$ or apoplexy or emboli$)).tw.
4. ((cerebral or intracerebral or intracranial or parenchymal or brain or intraventricular or brainstem or cerebellar or infratentorial or supratentorial or subarachnoid) adj (haemorrhage or hemorrhage or haematoma or hematoma or bleeding or aneurysm)).tw.
5. poststroke$.tw.
6. post-stroke.tw.
7. or/1–6
8. exp Rehabilitation/
9. exp Physical Therapy Modalities/
10. exp Therapy, Computer-Assisted/
11. exp Therapeutics/
12. (training or re-training or retraining or therap$ or rehabilitat$ or treatment$ or therapeutic$).tw.
13. or/8–12
14. 7 and 13
15. exp Cerebrovascular Disorders/rh [Rehabilitation]
16. or/14–15 (92807)
17. exp *child/ or exp *infant/
18. 16 not 17
19. animals/ not (animals/ and humans/)
20. 18 not 19
21. (addresses or bibliography or biography or comment or congresses or editorial or historical article or in vitro or interview or lectures or letter or news or newspaper article).pt.
22. 20 not 21
23. limit 22 to english language
24. limit 23 to yr=“2005 – 2008”
25. limit 23 to yr=“1990 – 2008”
26. meta-analysis.pt.
27. review.pt.
28. 26 or 27
29. 25 and 28
30. systematic.tw.
31. meta-analysis.tw.
32. metaanalysis.tw.
33. (cochrane adj2 review).tw.
34. meta-analysis.pt.
35. or/30–34
36. 29 and 35

### Systematic Reviews CDSR

1. stroke$ or cerebrovascular$ or cerebral vascular or CVA$).ti.
2. ((cerebral or cerebellar or brainstem or vertebrobasilar) adj5 (infarct$ or isch?emi$ or thrombo$ or apoplexy or emboli$)).ti.
3. ((cerebral or intracerebral or intracranial or parenchymal or brain or intraventricular or brainstem or cerebellar or infratentorial or supratentorial or subarachnoid) adj (haemorrhage or hemorrhage or haematoma or hematoma or bleeding or aneurysm)).ti.
4. poststroke$.ti.
5. post-stroke.ti.
6. or/1–5
7. (training or re-training or retraining or therap$ or rehabilitat$ or treatment$ or therapeutic$).tw.
8. and/6–7
9. limit 8 to yr=“2000 – 2008”