# Acronyms

2MWT: 2 meter walk test
5MWT: 5 meter walk test
10MWT: 10 meter walk test
6-m TWD: 6-minute timed walking distance
10-m TWS: 10-minute timed walking speed
ABC: Activities-Specific Balance Confidence Scale
ADL: Activities of Daily Living
AHRQ: Agency for Healthcare Research and Quality
AMAT: Arm Motor Ability Test
AMED: Allied and Complementary Medicine Database
AMT: Abbreviated Mental Test
APS: Aspiration-Penetration Scale
ARA: Action Research Arm Test
AS: Ashworth Scale
AT: Augmented therapy
BA: Before after study
BBS: Berg Balance Scale
BI: Barthel Index
BTX: Botulinum toxin type A
BWSTT: Body Weight Supported Treadmill Training
CaCo: Case control study
CCMFTR: Cochrane Complementary Medicine Field Trials Register
CCRCT: Cochrane Central Register of Controlled Trials (CENTRAL)
CCT: Controlled clinical trial
CDSR: Cochrane Database of Systematic Reviews
CGT: Conventional gait training
CIMT: Constraint-induced movement therapy
CINAHL: Cumulative Index to Nursing and Allied Health Literature
CIRRIE: Center for International Rehabilitation Research Information and Exchange
CMS: Center for Medicare and Medicaid Services
CMSA: Chedoke-McMaster Stroke assessment
Co: Control group
CO: Crossover trials
CONSORT: Consolidated Standards for Reporting Trials
COPM: Canadian Occupational Performance Measure
COVS: Clinical Outcome Variable Score
CPI: Clinical Practice Improvement
CR: Case report
CRS: Cross sectional study
CS: Case series
CSGTR: Cochrane Stroke Group Trials Register
CSS: Composite Spasticity Ccore
CT: Computerized tomography
CVA: Cerebral vascular accident
DEXA: Dual-energy x-ray absorptiometry
DM: Diabetes mellitus
EBP: Evidence-Based Practice
EGT: Electromechanical gait training
EGT-FES: Electromechanical gait training (with) functional electric stimulation
EMS: Elderly Mobility Scale
ES: Electrical stimulation
ESUS: Extended stroke unit service
FAC: Functional Ambulation Categories
FAME: Fitness and mobility exercise
FAP: Functional Ambulation Profile
FIM: Functional Independence Measure
FM: Fugl-Meyer
FOIS: Functional Oral Intake Scale
FP: Fucial pillar
GT: Gait trainer
HR: Health related
HRQoL: Health Related Quality of Life
ICF: International Classification of Functioning, Disability and Health
ILAS: Iowa Level of Assistance Scale
IM: Intramuscular
KB-ADL: Klein Bell Activities of Daily Living Scale
LOF: Length of followup
LOS: Length of stay
MAL: Motor Activity Log
mAS: Modified Ashworth Scale
MAS: Motor Assessment Scale
MBD: Multiple baseline design
MBS: Modified Barium Swallow
MCID: Minimal clinically important difference
MD: Medical doctor
MedCAC: Medicare Evidence Development and Coverage Advisory Committee
MI: Motricity Index
MMAS: Modified Motor Assessment Scale
MMSE: Mini-Mental State Examination
MRC: Medical Research Council
MRI: Magnetic resonance imaging
MU-EPC: McMaster University Evidence-based Practice Center
NA: Not applicable
NEADL: Nottingham Extended Activities of Daily Living
NG: Nasogastric
NHP: Nottingham Health Profile
NIH: National Institutes of Health
NIHSS: National Institute of Health Stroke Scale
NMES: Neuromuscular electric stimulation
NR: Not reported
NT: Not tested
OS: Observational study
OSUS: Ordinary stroke unit service
OT: Occupational Therapist
PASIPD: Physical Activity Scale for Individuals with Physical Disabilities
PED: Physiotherapy Evidence Database
PEG: Percutaneous endoscopic gastronomy
PICOT: Population, Intervention, Comparison, Outcome, Time
PR: Prospective study
PreP: Pre-post study
PT: Physical Therapy
PTA/OTA: Physiotherapy or Occupational Therapy Assistant
QE: Quasi-experimental study
QoL: Quality of Life
QRCT: Quasi-randomized clinical trial
RCT: Randomized controlled trial
RMI: Rivermead Mobility Index
ROM: Range of motion
RT: Recreational Therapist
SD: Standard deviation
sEMG: Surface electromyographic
SLP: Speech Language Pathologist
SPMSQ: Short Portable Mental Status Questionnaire
SR: Systematic review
SRM: Standardized Response Mean
SSRD: Single Subject Research Design
SSS: Scandinavian Stroke Scale
ST: Standard therapy
STROBE: Strengthening the Reporting of Observational Studies in Epidemiology
TEMPA: Test d’Evaluation des Membres superieurs des Personnes Agees
TS: Thermal-tactile stimulation
TT: Traditional therapy
TUG: Timed Up and Go test
UE: Upper extremity
WHO: World Health Organization
WIQ: Walking Impairment Questionnaire
WMFT: Wolf Motor Function Test
yrs: Years