# References

1 Congdon N, O'Colmain B, Klaver CC, et al. Causes and prevalence of visual impairment among adults in the United States. Arch Ophthalmol. 2004;122:477-85. [pmid: 15078664].
2 Bressler NM, Bressler SB, Congdon NG, et al. Potential public health impact of Age-Related Eye Disease Study results: AREDS report no. 11. [see comment]. Archives of Ophthalmology. 2003;121(11):1621-4. [pmid: 14609922].
3 Lee PP, Feldman ZW, Ostermann J, et al. Longitudinal prevalence of major eye diseases. Arch Ophthalmol. 2003;121:1303-10. [pmid: 12963614].
4 Eye Diseases Prevalence Research Group. Prevalence of age-related macular degeneration in the United States. Arch Ophthalmol. 2004;122:564-72. [pmid: 15078675].
5 Lee PP, Spritzer K, Hays RD. The impact of blurred vision on functioning and well-being. Ophthalmol. 1997;104(3):390-6.
6 Lindblad A, Clemons T. Responsiveness of the National Eye Institute Visual Function Questionnaire to progression to advanced age-related macular degeneration, vision loss and lens opacity. Arch Ophthalmol. 2005;123:1207-14. [pmid: 16157800].
7 Macular Photocoagulation Study Group. Visual outcome after laser photocoagulation for subfoveal choroidal neovascularization secondary to age-related macular degeneration. The influence of initial lesion size and initial visual acuity. Arch Ophthalmol. 1994;112(4):480-8. [pmid: 7512334].
8 Blinder KJ, Bradley S, Bressler NM, et al. Effect of lesion size, visual acuity, and lesion composition on visual acuity change with and without verteporfin therapy for choroidal neovascularization secondary to age-related macular degeneration: TAP and VIP report no. 1. Am J Ophthalmol. 2003;136(3):407-18. [pmid: 12967792].
9 V.I.S.I.O.N. Clinical Trial Group. Enhanced efficacy associated with early treatment of neovascular age-related macular degeneration with pegaptanib sodium: an exploratory analysis. Retina. 2005;25(7):815-27. [pmid: 16205558].
10 Danis RP, Ciulla TA, Pratt LM, et al. Intravitreal triamcinolone acetonide in exudative age-related macular degeneration. Retina. 2000;20(3):244-50. [pmid: 10872928].
11 Fine SL. Age-related macular degeneration 1969-2004: a 35-year personal perspective. Am J Ophthalmol. 2005;139(3):405-20. [pmid: 15767048].
12 Mangione CM, Phillips RS, Lawrence MG, et al. Improved visual function and attenuation of declines in health-related quality of life after cataract extraction. Arch Ophthalmol. 1994;112(11):1419-25. [pmid: 7980131].
13 Damiano AM, Steinberg EP, Cassard SD, et al. Comparison of generic versus disease-specific measures of functional impairment in patients with cataract. Med Care. 1995;33(4 suppl):AS120-30. [pmid: 7723440].
14 Rubin GS, Banden-Roche K, Huang GH. The association of multiple visual impairments with self-reported visual disability:SEE project. Invest Ophthalmol Vis Sci. 2001;42(1):64-72. [pmid: 11133849].
15 West S, Rubin G, Broman A, et al. How does visual impairment affect performance on tasks of everyday life? The SEE project. Arch Ophthalmol. 2002;120:774-80. [pmid: 12049583].
16 West SK, Rubin GS, Munoz B. Assessing functional status: correlation between performance on tasks conducted in a clinic setting and performance on the same task conducted at home. J Gerontol A Biol Sci Med Sci. 1997;52(4):M209-17. [pmid: 9224432].
17 Friedman DS, Munoz B, Rubin GS. Characteristics of discrepancies between self-reported visual function and measured reading speed. Salisbury Eye Evaluation Project Team. Invest Ophthalmol Vis Sci. 1999;40(5):858-64. [pmid: 10102282].
18 Elliott DB, Patla AE, Flanagan JG. The Waterloo Vision and Mobility Study: postural control strategies in subjects with ARM. Opthalmic Physiol Opt. 1995;15(6):553-9.
19 Hassan SE, Lovie-Kitchin J, Russell L. Vision and mobility performance of subjects with age-related macular degeneration. Optom Vis Sci. 2002;79(11):697-707. [pmid: 12462538].
20 Ergun E, Maar N, Radner W. Toth reading speed in macular translocation: Scotoma size and reading speed in patients with subfoveal occult choroidal neovascularization in age-related macular degeneration. Ophthalmol. 2003;110(1):65-9.
21 Mangione CM, Gutierrez PR, Lowe G, et al. Influence of age-related maculopathy on visual functioning and health-related quality of life. Am J Ophthalmol. 1999;128(1):45-53. [pmid: 10482093].
22 MacKenzie PJ, Chang TS, Scott IU, et al. Assessment of vision-related function in patients with age-related macular degeneration. Ophthalmol. 2002;109(4):720-9.
23 Dong LM, Childs AL, Mangione CM, et al. Health- and vision-related quality of life among patients with choroidal neovascularization secondary to age-related macular degeneration at enrollment in randomized trials of submacular surgery: SST report no. 4. Am J Ophthalmol. 2004;138(1):91-108. [pmid: 15234287].
24 Childs AL, Bressler NM, Bass EB, et al. Surgery for hemorrhagic choroidal neovascular lesions of age-related macular degeneration: quality-of-life findings: SST report no. 14. Ophthalmol. 2004;111(11):2007-14.
25 Miskala PH, Bass EB, Bressler NM, et al. Surgery for subfoveal choroidal neovascularization in age-related macular degeneration: quality-of-life findings: SST report no. 12. Ophthalmol. 2004;111(11):1981-92.
26 Reeves BC, Harper RA, Russell WB. Enhanced low vision rehabilitation for people with age related macular degeneration: a randomized controlled trial. Br J Ophthalmol. 2004;88(11):1443-9. [pmid: 15489491].
27 Stevenson MR, Hart PM, Chakravarthy U, et al. Visual functioning and quality of life in the SubFoveal Radiotherapy Study (SFRADS): SFRADS report 2. Br J Ophthalmol. 2005;89:1045-51. [pmid: 16024863].
28 Cahill MT, Stinnett SS, Banks A, et al. Quality of life after macular translocation with 360 degrees peripheral retinectomy for age-related macular degeneration. Ophthalmol. 2005;112(1):144-51.
29 Cahill MT, Banks AD, Stinnett SS, et al. Vision-related quality of life in patients with bilateral severe age-related macular degeneration. Ophthalmol. 2005;112(1):152-8.
30 Williams RA, Brody BL, Thomas RG, et al. The psychosocial impact of macular degeneration. Arch Ophthalmol. 1998;116(4):514-20. [pmid: 9565052].
31 Brody BL, Gamst AC, Williams RA. Depression, visual acuity, comorbidity, and disability associated with age-related macular degeneration. Ophthalmol. 2001;108(10):1893-900.
32 Lee JE, Fos PJ, Zuniga MA, et al. Assessing health-related quality of life in cataract patients: the relationship between utility and health-related quality of life measurement. Qual Life Res. 2000;9(10):1127-35. [pmid: 11401045].
33 Lee JE, Fos PJ, Zuniga MA, et al. Health-related quality of life of cataract patients: cross-cultural comparisons of utility and psychometric measures. Ophthalmic Epidemiology. 2003;10(3):177-91. [pmid: 12815492].
34 Pager CK, McCluskey PJ, Retsas C. Cataract surgery in Australia: a profile of patient-centered outcomes. Clin Exp Ophthalmol. 2004;32(4):388-92.
35 Tranos PG, Ghazi-Nouri SM, Rubin GS, et al. Visual function and subjective perception of visual ability after macular hole surgery. Am J Ophthalmol. 2004;138(6):995-1002. [pmid: 15629291].
36 Musch DC, Farjo AA, Meyer RF, et al. Assessment of health-related quality of life after corneal transplantation. Am J Ophthalmol. 1997;124(1):1-8. [pmid: 9222225].
37 Boisjoly H, Gresset J, Charest M, et al. The VF-14 index of visual function in recipients of a corneal graft: a 2-year follow-up study. Am J Ophthalmol. 2002;134(2):166-71. [pmid: 12140021].
38 Rosen PN, Kaplan RM, David K. Measuring outcomes of cataract surgery using the Quality of Well-Being Scale and VF-14 Visual Function Index. J Cataract Refract Surg. 2005;31(2):369-78. [pmid: 15767161].
39 Fryback DG, Dasbach EJ, Klein R. The Beaver Dam Health Outcomes Study: initial catalog of health-state quality factors. Med Decis Making. 1993;13(2):89-102. [pmid: 8483408].
40 Mangione CM, Lee PP, Gutierrez PR, et al. Development of the 25-item National Eye Institute Visual Function Questionnaire. Arch Ophthalmol. 2001;119(7):1050-8. [pmid: 11448327].
41 Kupersmith MJ, Speira R, Langer R, et al. Visual function and quality of life among patients with giant cell (temporal) arteritis. J Neuroophthalmol. 2001;21(4):266-73. [pmid: 11756857].
42 Linder M, Chang TS, Scott IU, et al. Validity of the visual function index (VF-14) in patients with retinal disease. Arch Ophthalmol. 1999;117(12):1611-6. [pmid: 10604665].
43 Mangione CM, Orav EJ, Lawrence MG, et al. Predictions of visual function after cataract surgery. A prospectively validated model. Arch Ophthalmol. 1995;113(10):1305-11. [pmid: 7575265].
44 Pesudovs K, Coster DJ. An instrument for assessment of subjective visual disability in cataract patients. Br J Ophthalmol. 1998;82(6):617-24. [pmid: 9797660].
45 Superstein R, Boyaner D, Overbury O. Functional complaints, visual acuity, spatial contrast sensitivity, and glare disability in preoperative and postoperative cataract patients. J Cataract Refract Surg. 1999;25(4):575-81. [pmid: 10198867].
46 McGwin G Jr, Scilley K, Brown J, et al. Impact of cataract surgery on self-reported visual difficulties: comparison with a no-surgery reference group. J Cataract Refract Surg. 2003;29(5):941-8. [pmid: 12781280].
47 Pesudovs K, Garamendi E, Keeves JP, et al. The Activities of Daily Vision Scale for cataract surgery outcomes: reevaluating validity with Rasch analysis. Invest Ophthalmol Vis Sci. 2003;44(7):2892-99. [pmid: 12824228].
48 Tranos PG, Topouzis F, Stangos NT, et al. Effect of laser photocoagulation treatment for diabetic macular oedema on patient's vision-related quality of life. Curr Eye Res. 2004;29(1):41-9. [pmid: 15370366].
49 Submacular Surgery Trials Research Group. Health- and vision-related quality of life among patients with ocular histoplasmosis or idiopathic choroidal neovascularization at enrollment in a randomized trial of submacular surgery: Submacular Surgery Trials Report No. 5. Arch Ophthalmol. 2005;123(1):78-88. [pmid: 15642816].
50 Kymes SM, Walline JJ, Zadnik K, et al. Quality of life in keratoconus. Am J Ophthalmol. 2004;138(4):527-35. [pmid: 15488776].
51 Fink BA, Wagner H, Steger-May K, et al. Differences in keratoconus as a function of gender. Am J Ophthalmol. 2005;140(3):459-68. [pmid: 16083843].
52 Tinley CG, Frost A, Hakin KN, et al. Is visual outcome compromised when next day review is omitted after phacoemulsification surgery? A randomized control trial. British Journal of Ophthalmology. 2003;87(11):1350-5. [pmid: 14609832].
53 Steinberg E, Tielsch JM, Schein OD. The VF-14: an index of functional impairment in patients with cataract. Arch Ophthalmol. 1994;112:630-8. [pmid: 8185520].
54 Steinberg EP, Tielsch JM, Schein OD, et al. National study of cataract surgery outcomes. Variation in 4-month postoperative outcomes as reflected in multiple outcome measures. Ophthalmol. 1994;101(6):1131-40. discussion 1140-1.
55 Schein OD, Steinberg EP, Cassard SD, et al. Predictors of outcome in patients who underwent cataract surgery. Ophthalmol. 1995;102(5):817-23.
56 Cassard SD, Patrick DL, Damiano AM, Legro M, et al. Reproducibility and responsiveness of the CF-14: an index of functional impairment in patients with cataracts. Arch Ophthalmol. 1995;113(12):1508-13. [pmid: 7487617].
57 Desai P, Reidy A, Minassian DC, et al. Gains from cataract surgery: visual function and quality of life. Br J Ophthalmol. 1996;80(10):868-73. [pmid: 8976696].
58 Alonso J, Espallargues M, Andersen TF. International applicability of the VF-14: an index of visual function in patients with cataracts. Ophthalmol. 1997;104:799-807.
59 Espallargues M, Alonso J. Effectiveness of cataract surgery in Barcelona, Spain site results of an international study. Barcelona PORT investigators. International Patient Outcomes Research Team. J Clin Epidemiol. 1998;51(10):843-52. [pmid: 9762877].
60 Norregaard JC, Bernth-Petersen P, Alonso J, et al. Variations in indications for cataract surgery in the United States, Denmark, Canada and Spain: results from the International Cataract Surgery Outcomes Study. Br J Ophthalmol. 1998;10(1101-2).
61 Castells X, Alonso J, Ribo C, et al. Comparison of the results of first and second cataract eye surgery. Ophthalmol. 1999;106(4):676-82.
62 Crabtree HL, Hildreth AJ, O'Connell JE, et al. Measuring visual symptoms in British cataract patients: the cataract symptom scale. [see comment]. Br J Ophthalmol. 1999;83(5):519-23. [pmid: 10216047].
63 Rose K, Waterman H, Toon L, et al. Management of day surgery patients with cataract attending a peripheral ophthalmic clinic. Eye. 1999;13(Pt 1):71-5. [pmid: 10396388].
64 Brydon KW, Tokarewicz AC, Nichols BD. AMO array multifocal lens versus monofocal correction in cataract surgery. J Cataract Refract Surg. 2000;(26):1. [pmid: 10646128].
65 Lum F, Schein O, Schachat AP, et al. Initial two years of experience with the AO National Eyecare Outcomes Network (NEON) cataract surgery database. Ophthalmol. 2000;107(4):691-7.
66 Norregaard JC, Bernth-Petersen P, Alosnso J, et al. Visual functional outcomes of cataract surgery in the United States, Canada, Denmark, and Spain: report of the International Cataract Surgery Outcomes Study. J Cataract Refract Surg. 2003;11:2135-42. [pmid: 14670422].
67 Mozaffarieh M, Krepler K, Heinzl H, et al. Visual function, quality of life and patient satisfaction after ophthalmic surgery: a comparative study. Ophthalmologica. 2004;218(1):26-30. [pmid: 14688432].
68 Goyal R, Shankar J, Sullivan S. Referrals for cataract surgery: variations between different geographic areas within a Welsh Health Authority. Eye. 2004;(18):8.
69 Aralikatti AK, Tu KL, Kamath GG, et al. Outcomes of sulcus implantation of Array multifocal intraocular lenses in second-eye cataract surgery complicated by vitreous loss. J Cataract Refract Surg. 2004;30(1):162-7.
70 Mozaffarieh M, Heinzl H, Sacu S, et al. Clinical outcomes of phacoemulsification cataract surgery in diabetes patients: visual function (VF-14), visual acuity and patient satisfaction. Acta Ophthalmol Scand. 2005;83(2):176-83. [pmid: 15799729].
71 Valderas JM, Rue M, Guyatt G, et al. The impact of the VF-14 index, a perceived visual function measure, in the routine management of cataract patients. Qual Life Res. 2005;14(7):1743-53. [pmid: 16119185].
72 Lee JE, Fos PJ, Sung JH, et al. Relationship of cataract symptoms of preoperative patients and vision-related quality of life. Qual Life Res. 2005;14(8):1845-53. [pmid: 16155772].
73 Margolis MK, Coyne K, Kennedy-Martin T, et al. Vision-specific instruments for the assessment of health-related quality of life and visual functioning: a literature review. Pharmacoeconomics. 2002;20(12):791-812. [pmid: 12236802].
74 de Boer MR, Moll AC, de Vet HC, et al. Psychometric properties of vision-related quality of life questionnaires: a systematic review. Ophthalmic Physiol Opt. 2004;24(4):257-73. [pmid: 15228503].
75 Lamping DL, Schroter S, Marquis P, et al. The community-acquired pneumonia symptom quesitonnaire. Chest. 2002;122(3):920-9. [pmid: 12226033].
76 Gresset J, Boisjoly H, Nguyen TQ, et al. Validation of French-language versions of the Visual Functioning Index (VF-14) and the Cataract Symptom Score. Can J Ophthalmol. 1997;32:31-7. [pmid: 9047031].
77 Velozo CA, Lai JS, Mallison T. Maintaining instrument quality while reducing items: application of Rasch analysis to a self-report of visual function. J Outcome Meas. 2001;4(3):667-80. [pmid: 11253902].
78 Sharma S, Brown G, Brown M, et al. Validity of the time trade-off and standard gamble methods of utility assessment in retinal patients. Br J Ophthalmol. 2002;86(5):493-6. [pmid: 11973240].
79 Riusala A, Sarna S, Immonen I. Visual function index (VF-14) in exudative age-related macular degeneration of long duration. Am J Ophthalmol. 2003;135(2):206-12. [pmid: 12566025].
80 Armbrecht AM, Aspinall PA, Dhillon B. A prospective study of visual function and quality of life following PDT in patients with wet age related macular degeneration. Br J Ophthalmol. 2004;88(10):1270-3. [pmid: 15377549].
81 Javitt JC, Steinberg EP, Sharkey P, et al. Cataract surgery in one eye or both. A billion dollar per year issue. Ophthalmol. 1995;102(11):1583-92. discussion 1592-3.
82 Tielsch JM, Steinberg E, Cassard SD, et al. Preoperative functional expectations and postopeartive outcomes among patients undergoing first eye cataract surgery. Arch Ophthalmol. 1995;113(10):1312-18. [pmid: 7575266].
83 Armbrecht AM, Findlay C, Aspinall PA, et al. Cataract surgery in patients with age-related macular degeneration: one-year outcomes. J Cataract Refract Surg. 2003;29(4):686-93. [pmid: 12686235].
84 Nijkamp MD, Nuijts RM, Borne B, et al. Determinants of patient satisfaction after cataract surgery in 3 settings. J Cataract Refract Surg. 2000;26(9):1379-88. [pmid: 11020624].
85 Mangione CM, Lee PP, Pitts J, et al. Psychometric properties of the National Eye Institute Visual Function Questionnaire (NEI-VFQ). Arch Ophthalmol. 1998;116:1496-504. [pmid: 9823352].
86 Mangione CM, Berry S, Spritzer K, et al. Identifying the content area for the 51-item National Eye Institute Visual Function Questionnaire: results from focus groups with visually impaired persons. Arch Ophthalmol. 1998;116(2):227-33. [pmid: 9488276].
87 Maguire M, Complications of Age-Related Macular Degeneration Prevention Trial Research Group. Baseline characteristics, the 25-Item National Eye Institute Visual Functioning Questionnaire, and their associations in the Complications of Age-Related Macular Degeneration Prevention Trial (CAPT). Ophthalmol. 2004;111(7):1307-16.
88 Massof RW, Fletcher DC. Evaluation of the NEI visual functioning questionnaire as an interval measure of visual ability in low vision. Vision Res. 2001;41(3):397-413. [pmid: 11164454].
89 Clemons TE, Chew EY, Bressler SB, et al. National Eye Institute Visual Function Questionnaire in the Age-Related Eye Disease Study (AREDS): AREDS Report No. 10. Arch Ophthalmol. 2003;121(2):211-7. [pmid: 12583787].
90 Berdeaux GH, Nordmann JP, Colin E, et al. Vision-related quality of life in patients suffering from age-related macular degeneration. Am J Ophthalmol. 2005;139(2):271-9. [pmid: 15733988].
91 Miskala PH, Hawkins BS, Mangione CM, et al. Responsiveness of the National Eye Institute Visual Function Questionnaire to changes in visual acuity: findings in patients with subfoveal choroidal neovascularization--SST Report No. 1. [erratum appears in Arch Ophthalmol 2003 Oct;121(10):1513]. Arch Ophthalmol. 2003;121(4):531-9. [pmid: 12695250].
92 Miskala PH, Bressler NM, Meinert CL. Relative contributions of reduced vision and general health to NEI-VFQ scores in patients with neovascular age-related macular degeneration. Arch Ophthalmol. 2004;122(5):758-66. [pmid: 15136325].
93 Brody BL, Roch-Levecq AC, Thomas RG, et al. Self-management of age-related macular degeneration at the 6-month follow-up: a randomized controlled trial. Arch Ophthalmol. 2005;123(1):46-53. [pmid: 15642811].
94 Scilley K, DeCarlo DK, Wells J, et al. Vision-specific health-related quality of life in age-related maculopathy patients presenting for low vision services. Ophthalmic Epidemiol. 2004;11(2):131-46. [pmid: 15255028].
95 Elliott DB, Patla AE, Furniss M, et al. Improvements in clinical and functional vision and quality of life after second eye cataract surgery. Optom Vis Sci. 2000;77(1):13-24. [pmid: 10654854].
96 West SK, Munoz B, Rubin GS. Function and visual impairment in a population-based study of older adults. Invest Ophthalmol Vis Sci. 1997;38:72-82. [pmid: 9008632].
97 Scilley K, Jackson GR, Cideciyan AV, et al. Early age-related maculopathy and self-reported visual difficulty in daily life. Ophthalmol. 2002;109(7):1235-42.
98 Frost NA, Sparrow JM, Durant JS, et al. Development of a questionnaire for measurement of vision-related quality of life. Ophthalmic Epidemiol. 1998;5(4):185-210. [pmid: 9894804].
99 Hart PM, Chakravarthy U, Stevenson MR, et al. A vision specific functional index for use in patients with age related macular degeneration. Br J Ophthalmol. 1999;83:1115-20. [pmid: 10502569].
100 Hart PM, Stevenson MR, Montgomery AM, et al. Further validation of the Daily Living Tasks Dependent on Vision: Identification of domains. Br J Ophthalmol. 2005;89:1127-30. [pmid: 16113365].
101 Stevenson MR, Hart PM, Montgomery AM, McCulloch DW, et al. Reduced vision in older adults with age related macular degeneration interferes with ability to care for self and impairs role as carer. Br J Ophthalmol. 2004;88:1125-30. [pmid: 15317701].
102 McClure ME, Hart PM, Jackson AJ, et al. Macular degeneration: do conventional measurements of impaired visual function equate with visual disability?. Br J Ophthalmol. 2000;84:244-50. [pmid: 10684832].
103 Casten RJ, Rovner BW, Tasman W. Age-related macular degeneration and depression: a review of recent research. Curr Opin Ophthalmol. 2004;15(3):181-3. [pmid: 15118503].
104 Janz NK, Wren PA, Lichter PR, et al. Quality of life in newly diagnosed glaucoma patients : The Collaborative Initial Glaucoma Treatment Study. Ophthalmology. 2001;108(5):887-97. discussion 898. [pmid: 11320018].
105 Owsley C, McGwin G Jr. Depression and the 25-item National Eye Institute Visual Function Questionnaire in older adults. Ophthalmol. 2004;111(12):2259-64.
106 Miskala PH, Bressler NM, Meinert CL. Is adjustment of National Eye Institute Visual Function Questionnaire scores for general health necessary in randomized trials?. Am J Ophthalmol. 2004;137(5):961-3. [pmid: 15126176].
107 Frost A, Eachus J, Sparrow J, et al. Vision-related quality of life impairment in an elderly UK population: associations with age, sex, social class and material deprivation. Eye. 2001;15(Pt 6):739-44. [pmid: 11826994].
108 Tielsch JM, Sommer A, Katz J. Socioeconomic status and visual impairment among urban Americans. Baltimore Eye Research Group. Arch Ophthalmol. 1991;109(5):637-41. [pmid: 2025164].
109 Globe D, Varma R, Azen SP. Psychometric performance of the NEI VFQ-25 in visually normal Latinos: the Los Angeles Eye Study. Invest Ophthalmol Vis Sci. 2003;44(4):1470-8. [pmid: 12657581].
110 Childs AL, Submacular Surgery Trials Research Group. Effect of order of administration of health-related quality of life interview instruments on responses. Qual Life Res. 2005;14(2):493-500. [pmid: 15892438].
111 Mangione CM, Lee PP, Hays R. Measurement of visual functioning of health-related quality of life in eye disease and cataract surgery. Spilker B, editor. Quality of life and pharmacoeconomics in clinical trials. second edition. NY. Raven Press. 1995.
112 Brown G. Vision and quality-of-life. Trans Am Ophthalmol Soc. 1999;97:473-511. [pmid: 10703139].
113 Brown G, Brown M, Sharma S. Difference between ophthalmologists' and patients' perceptions of quality of life associated with age-related macular degeneration. Can J Ophthalmol. 2000;35(3):127-33. [pmid: 10812481].
114 Sharma S, Hollands H, Brown GC, et al. Improvement in quality of life from photodynamic therapy: a Canadian perspective. Can J Ophthalmol. 2001;36(6):332-8. [pmid: 11714119].
115 Brown M, Brown G, Sharma S, et al. Utility values and diabetic retinopathy. Am J Ophthalmol. 1999;128(3):324-30. [pmid: 10511027].
116 Brown G, Sharma S, Brown M, et al. Utility values and age-related macular degeneration. Arch Ophthalmol. 2000;118(1):47-51. [pmid: 10636413].
117 Sharma S, Oliver-Fernandez A, Bakal J, et al. Utilities associated with diabetic retinopathy: results from a Canadian sample. Br J Ophthalmol. 2003;87(3):259-61. [pmid: 12598432].
118 Stein JD, Brown M, Brown G, et al. Quality of life with macular degeneration: perceptions of patients, clinicians, and community members. Br J Ophthalmol. 2003;87(1):8-12. [pmid: 12488253].
119 Shah V, Gupta S, Shah KV, et al. TTO utility scores measure quality of life in patients with visual morbidity due to diabetic retinopathy or ARMD. Ophthalmic Epidemiol. 2004;11(1):43-51. [pmid: 14977496].
120 Nease RF, Whitcup SM, Ellwein LB, et al. Utility-based estimates of the relative morbidity of visual impairment and angina. Ophthalmic Epidemiol. 2000;7(3):169-85. [pmid: 11035553].
121 Samsa G, Edelman D, Rothman ML, et al. Determining clinically important differences in health status measures: a general approach with illustration to the health utilities mark II. PharmacoEconomics. 1999;2:141-55. [pmid: 10351188].