# Summary

The current review supports the following conclusions regarding the specific questions posed by CMS:

1. There are several validated and clinically responsive vision-specific instruments for measuring health-related quality of life in individuals with AMD, including the NEI-VFQ and the VF-14 questionnaires. General health-related QoL instruments such as the SF-36, SIP, or similar instruments are generally insensitive to the presence of specific eye diseases, although they may be more responsive to visual symptoms. As such, vision-specific, patient-based survey instruments both have been widely used and shown to be sensitive to differences in visual status and functioning among patients with AMD and various levels of severity of AMD. The use of observational testing of actual performance appears promising but has not been published in randomized clinical trials in patients with AMD to date, but case series evidence suggests that observed reading performance may be a useful adjunct related to important patient-centered considerations.
2. These vision-specific QoL measuring methods have been successfully applied to other eye diseases affecting central vision. In particular, the NEI-VFQ and VF-14 have been widely used in other eye diseases, such as cataract, diabetic macular edema, diabetic retinopathy, vein occlusion, and corneal diseases. As such, their use provides an ability to compare the impact of AMD with other eye diseases and the attendant treatments to each other. This also provides additional support for the use of these instruments to provide additional information in assessing the impact of disease and treatments on patients with AMD.
3. These methods, in particular the NEI-VFQ and VF-14, have appropriate psychometric properties for use in AMD and other diseases affecting central vision. In many different analyses among different populations, the scales and summary (unweighted) scores of the VF-14 and NEI-VFQ have been found to be reliable (both internal consistency among scales and test-retest over time and across methods), valid (content, construct, concurrent, discriminant), and responsive to important clinical and functioning dimensions. Importantly, the questions in the NEI-VFQ related to difficulty have been found to be valid by Rasch analysis as well, although the psychological and emotional scales were not assessable by Rasch analysis. The NEI-VFQ includes psychosocial issues in addition to activity or task difficulty.
4. The NEI-VFQ and VF-14 have been found to correlate moderately (0.2 to 0.4 generally) with traditional visual performance measures such as visual acuity, reading speed, and contrast sensitivity. The NEI-VFQ has been further tested in therapeutic interventions and found to have excellent responsiveness in trials in which visual (and anatomical) improvement has occurred as well as in trials in which these parameters have deteriorated. Ten-point differences in overall or subset scores have correlated with 15-letter changes in visual acuity in patients with macular degeneration. Use of the NEI-VFQ has also revealed similar levels of relationship between changes in the NEI-VFQ and visual acuity in population based studies as well as AMD patients.
5. Vision-specific QoL instruments may provide complementary information to conventional measurement tools such as visual acuity, and may provide a more patient-centered orientation to assessing functioning among patients with AMD. Evidence for the complementary nature of these measures comes from several findings. First, the NEI-VFQ and VF-14 have been found to correlate only moderately (0.3 to 0.4 typically) with visual acuity, reading speed, and contrast sensitivity, suggesting that they reflect somewhat different dimensions. Second, scores on the VF-14 are more highly correlated with overall satisfaction with or quality of vision (and satisfaction after cataract surgery) than the traditional performance measure of visual acuity. Third, correlations with visual acuity and disease severity are better for later stages of disease and visual acuity loss, suggesting that greater variance in NEI-VFQ scores among patients in early stages without significant visual acuity loss reflect patient difficulties and perceptual issues not reflected in visual acuity and other traditional measures. As such, the choice of primary endpoints may differ based on the specific questions being asked. While there is a direct relationship between conventional measurement tools such as visual acuity and contrast sensitivity to observed performance on important activities such as using a key, reading, and mobility, there is also an imprecise relationship among these conventional measures and patient self-reported visual functioning as measured by questionnaire instruments. Using conventional measures, patient reported functioning, or a combination may depend on the relative importance of assessing patient functioning as opposed to physician measured and more “objective” measures of visual abilities. Finally, these QoL measures assess the impact of disease on the person level and can reflect the full impact of the disease on the person, including emotional effects and the side effects of treatment.
6. Consideration should be given to including adjustments for time since diagnosis, depression, general health status, socioeconomic status (pending additional investigation), language used in the instrument (if applicable), and standard psychometric issues such as questionnaire order and mode of administration in analyzing scores with the vision-specific QoL instruments.
7. Additional work is needed to understand the relationship of proxy measures such as the vision-specific QoL instruments with actual observed or “objective” performance on the part of patients with AMD and on other potential outcomes measures for treatment or rehabilitation of AMD related deficits. While small studies assessing a specific task have been performed, analysis of the SEE project and other datasets may provide an invaluable contribution to our understanding of the impact of AMD on patient functioning and general abilities to function. Additional work on the value of depression and other psychosocial and emotional measures as independent outcomes endpoints would also be helpful.