# Clinical Implications

As described in Section 1, the key clinical issue in AMD is whether the biological impact of treatments corresponds to differences that patients care about. Usually, this issue is formulated as a question of “clinically important differences.” In the literature, clinically important differences are assessed in various ways, the two primary approaches being termed distribution-based and anchor-based.121 In the distribution-based approach, either change scores (longitudinal designs) or differences between group means (cross-sectional designs) are compared against statistically derived benchmarks, usually reported in standard deviation units. For cross-sectional designs, differences of 0.2 standard deviation units are considered to be small, differences of 0.5 standard deviation units are considered to be moderate, and differences of 0.8 standard deviation units are considered to be large. The VF-14 total score has an approximate standard deviation of 20;^58^ accordingly, these benchmarks are 4, 10, and 16. The NEI-VFQ-25 total score has an approximate standard deviation of 14;^89^ accordingly, these benchmarks are 3, 7, and 11. Standard deviation for subscale scores is larger; thus, so are the corresponding distribution-based effect size anchors. In practice, these standard deviations also depend on the population under study.

Anchor-based approaches compare observed changes (longitudinal designs) or between-group differences (cross-sectional designs) with either patient or clinician report. For example, in a longitudinal design (e.g., an assessment of cataract surgery) an anchor-based approach based on patient report would be to select the subset of patients that reported overall improvement in their quality of life (e.g., using a global item) and then calculate the mean change in the QoL measure in question. Following this same idea, the minimal clinically important difference can be estimated by performing a similar calculation for the subset of patients reporting small improvements in overall quality of life. As an example of a clinician-reported approach, suppose that the question under consideration is whether a 10-unit difference in the NEI-VFQ is clinically important. Two typical patients could be envisioned, differing in their NEI-VFQ scores by 10 units, the pattern of the differences in their items analyzed, and an assessment made whether this difference represents something likely to be meaningful to patients.

In the literature, the question of clinically meaningful difference in eye disease is far from resolved. To get some sense of what score differences mean, we offer three observations. First, from studies of cataract surgery,6,56 an intervention with a vivid improvement, QoL measures improve by an order of 1 standard deviation unit. Thus, a clinically meaningful difference is certainly below this value.

Second, visual acuity can be a useful reference point. In Table 5 we provide ranges of QoL responses for the VF-14 and the NEI-VFQ for different levels of visual acuity. We see a general correspondence between acuity and quality of life; individuals with acuity worse than 20/200, the threshold for legal blindness, on average experience roughly a 50-point drop compared with individuals with no or mild visual acuity deficit. Further, for both instruments, a 10-point drop corresponds to a 15-letter visual acuity loss.3,82

Table 5 Mean QoL results by categories of visual acuity

Visual acuity in better eye (reference) | VF-14^53,78,82^ | NEI-VFQ89,91
20/20 to 20/40 | 83, 83, 90 | 94, 81
20/50 to 20/70 | 73, 76, 79
20/80 to 20/100 | 70, 74, 51 | 52
≤ 20/200 | 69, 34 | 46

Third, the scores in the QoL instruments have concrete interpretations that give some sense of the practical implications of specific point drops (or, conversely, point rises). The following are illustrative examples. For the NEI-VFQ, regarding work or hobbies (“How much difficulty do you have doing work or hobbies that require you to see well up close, such as cooking, sewing, fixing things around the house, or using hand tools?”), a change in response from “No difficulty at all” to “Stopped doing this because of your eyesight” corresponds to a 4-point drop. A change in response from “Driving” to “Not driving because of eyesight” corresponds to a 4-point drop. Relating to impact on perception, for example a change in response to the statement “I worry about doing things that will embarrass myself or others because of my eyesight” from “definitely false” to “definitely true” corresponds to a 4-point drop. Change in frequency of performance of an activity leads to NEI-VFQ score reductions. For example, if the response to “Are you limited in how long you can work or do other activities because of your vision?” changes from “None of the time” to “Some of the time,” the NEI-VFQ score drops by 2 points; from “None of the time” to “All of the time” leads to a 4-point drop. The impact of limitations on score is similar for the VF-14. For example, for the question “Do you have any difficulty even with glasses writing checks or filling out forms?,” a change from “No” to “Yes with a great deal of difficulty” reduces score by roughly 5 points, as does a similar effect on reading a newspaper or book. (Note that if an individual does not perform the activity for reasons other than vision, it is not included in the score and the remaining elements are renormalized to keep the score from 0 to 100.)