# Results

## 3.1 QoL Instruments and AMD

Question 1a: What QoL measurement methods have been used in the AMD population and in those with visual disabilities from AMD?

The use of health-related QoL measures for the evaluation of AMD is a relatively recent concept, starting within the last 20 years. Vision-related, health-related quality of life can be conceptualized in various ways, primary among these being (a) observed task performance; (b) general health-related QoL measures applied, with or without modification, to patients with vision loss; and (c) vision-specific measures, including vision-specific measures of visual performance and vision-specific measures of health-related quality of life. Each of these can be contrasted with conventional clinical measures of visual performance, for example, provider-involved tests such as visual acuity or contrast sensitivity.

### 3.1.1 Observed Task Performance Measures

Relatively few studies have assessed objective task performance as a means of gauging the limitations of patients with AMD. Accordingly, discussion of this approach will be limited to the current section.

The SEE project is the largest population-based study among elders in the United States where participants were observed performing essential tasks such as face recognition, use of keys, mobility and obstacle avoidance, and reading, as well as being asked about their functioning through the administration of both general and vision-specific QoL instruments. Participants also received comprehensive assessments of their visual performance with conventional measures (provider-directed) such as visual acuity, contrast sensitivity, and visual fields.15 The project has not yet published data specific to patients with AMD, but those with AMD were included in the study sample. The project has already generated several key findings: 1) in-office observation of task performance by elders closely parallels actual at-home task performance;16 2) observed task performance in reading correlates with self-reported difficulty in reading, but with significant variability from patient to patient;17 and 3) in-office conventional examination measures and patient self-report of visual activities and functions provide complementary data.14

Several smaller studies (almost exclusively case series) have examined specific tasks, particularly reading and mobility.18-20 These studies indicate that the size, severity, and location of the central vision loss (“scotoma”) caused by advanced AMD play a particularly important role in modulating the impact of AMD on patient functioning. Studies that utilize direct observation of measured performance require greater levels of effort and participation on the part of both patients and observers (researchers or patient care providers), as well as the availability of standardized testing environments and equipment. Because of these issues, direct observation may not be practical in assessing functioning in ordinary clinical care or in standardized, large sample-size studies. However, those patients who receive home visit assessments for safety and other visiting nurse services may be appropriate candidates for such measures.

### 3.1.2 General Health-Related QoL Measures

Rather than focus on observed task performance, researchers have typically measured visual functioning and health-related quality of life using questionnaires. Several studies have assessed the ability of global or general health-related QoL instruments such as the SF-36 and its variants (the SF-12 and the Medical Outcomes Study 20-Item Short Form [MOS-20]) to detect the impact of having AMD, worsening of AMD and visual performance, and the relative impact of treatment regimens to alter the natural history of AMD as measured by physiological parameters or conventional visual performance. Such global instruments detect physical, mental, and social impact across the spectrum of systemic and disease processes. It has been hypothesized that global measures may not be sensitive to detect subtle vision changes or treatment of eye conditions, as noted with cataracts,12 and, indeed, the psychometric data support this conclusion21-27 (see response to Question 1c), in particular regarding convergent validity with objective measures.21-26,28-30 MEDLINE searches with “amd” or “armd” and the Quality of Well-Being Scale (QWB), EuroQol, and General Health Questionnaire (GHQ) separately did not uncover any published papers. A similar search with “amd” and the SIP revealed one paper.31 For the present purposes, the modification of the SIP pertaining to patients with visual deficits is considered to be a global rather than a vision-specific measure.

Overall, because the vision-specific measures appear to have better performance relative to clinical features of AMD of importance to patients when compared to general QoL measures, the primary focus of our efforts will be on vision-specific approaches.

### 3.1.3 Vision-Specific Measures

During the last 15 years, a myriad of vision-specific instruments have been developed, both for specific eye diseases and for a spectrum of eye diseases. Some of these instruments assess visual function and visual abilities in the context of daily activities, and are termed patient-based measures of visual function. Other instruments assess patient reactions and concerns relative to their eye diseases, and are termed vision-related or vision-specific QoL measures.

Some of the instruments originally developed for cataract and cataract surgery assessment have subsequently been used in other eye diseases, including AMD. Two instruments, the National Eye Institute Visual Functioning Questionnaire (NEI-VFQ) and the Vision Quality of Life Core Measure (VCM1), were expressly designed to be usable across major eye conditions of interest (cataract, glaucoma, macular degeneration, and diabetic retinopathy in the case of the NEI-VFQ), with additional questions for specific diseases in the NEI-VFQ (“additional module questions”). Others have recently been developed specifically for AMD. In a literature search of QoL instruments applied in the evaluation of AMD disease burden or effects of therapy, we found five such instruments, discussed below: 1) the Visual Function Index (VF-14); 2) the NEI-VFQ; 3) the Activities of Daily Vision Scale (ADVS); 4) the VCM1; and 5) the Daily Living Tasks Dependent on Vision (DLTV). Appendix D contains copies of these instruments, and Table 1 summarizes their content and administration features.

Table 1 Content and administration features of QoL instruments used with AMD patients

CONTENT | ADVS | DLTV | NEI-VFQ-25 | VF-14 | VCM1
How would you evaluate your general health? | | | ✓
How would you evaluate your general vision? | ✓ | ✓ | ✓
Do you experience any ocular pain? | | | ✓
Do you have trouble seeing in dim light or at night? | ✓
Can you see objects off to the side? | | ✓ | ✓
Can you see moving objects at night? | ✓
Are you confident using public transportation? | ✓
Are you confident walking around your own neighborhood? | | ✓
Are you confident walking around an unfamiliar area? | | ✓
Do you have difficulty driving? | | | ✓ | ✓
Do you have difficulty driving in daytime? | ✓ | | ✓ | ✓
Do you have difficulty driving at night? | ✓ | | ✓ | ✓
Do you have difficulty driving in busy conditions? | | | ✓
Do you have difficulty driving in unfamiliar areas? | ✓
Do oncoming headlights bother you? | ✓
Can you see things in the distance? | ✓ | ✓ | ✓ | ✓
Can you enjoy the scenery while traveling? | | ✓
Can you read signs across the street? | | ✓ | ✓ | ✓
Can you read signs during bright daylight? | ✓
Can you read signs at night or in dim light? | ✓
Can you read correspondence? | | ✓
Can you read food can labels? | ✓ | | | ✓
Can you read large-print materials? | | | | ✓
Can you read medicine bottle labels? | ✓ | ✓ | | ✓
Can you read the newspaper? | ✓ | ✓ | | ✓
Can you see television? | | ✓ | ✓ | ✓
Can you read the writing on television? | ✓
Do you have difficulty walking downstairs? | | ✓ | | ✓
Do you have difficulty walking downstairs in bright daylight? | ✓
Do you have difficulty walking downstairs in dim light or at night? | ✓ | | ✓
Can you see the numbers on a phone?
Can you see things that are close to you? | ✓ | ✓ | ✓ | ✓
Can you identify money in your wallet? | | ✓
Can see to pay bills accurately? | | | ✓
Can you see to write checks? | ✓ | ✓ | | ✓
Can you tend to your own personal hygiene needs? | | ✓ | ✓
Can you cut the food on your own plate? | | ✓
Do you have trouble finding Items on a crowded shelf? | | | ✓
Can you pick out and match your own clothes? | | | ✓
Can you pour yourself a drink? | | ✓
Can you prepare meals? | ✓ | ✓ | ✓ | ✓
Can you thread a needle? | ✓
Can you use a ruler/tape measure? | ✓
Do you have difficulty using a screwdriver? | ✓
Do you have difficulty doing fine handwork? | | | ✓ | ✓
Are you able to enjoy gardening? | | ✓
Can you see to play cards/games? | ✓ | | | ✓
Can you see to play sports? | | | ✓ | ✓
Can you recognize colors? | | | ✓
Can you recognize faces? | ✓ | ✓ | ✓ | ✓
Can you see movies/sports events? | | | ✓
Life Interference | | | | | ✓
Safety outside the home | | | | | ✓
Anger | | | | | ✓
Depression | | | | | ✓
Coping with everyday life | | | | | ✓
Inability to do preferred activities | | | | | ✓
Fear of deterioration in vision | | | | | ✓
Safety at home | | | | | ✓
Embarrassment | | | | | ✓
Loneliness | | | | | ✓
ADMINISTRATION
Time to complete instrument | | | 10 min. avg. | | 30-90 min.
Mode of administration:
Phone interview | ✓ | | ✓ | ✓
Face-to-face interview | ✓ | ✓ | ✓ | ✓ | ✓
Mail questionnaire
In-office questionnaire | | ✓ | ✓ | ✓ | ✓
Observation
Scoring | See Note 1 | See Note 2 | See Note 3 | See Note 4 | See Note 5

Note 1 Items were examined with multiple (usually three) questions per item: the first to assess whether patient engages in the activity (if “not applicable” the answer was treated as missing data), the second to establish “no difficulty” (5) to “extreme difficulty” (2), and the third to ask whether the patient is unable to perform the activity because of poor vision (if not, it is missing data; if so, then the most disabled score [1] is assigned). For this study, all questions were equally weighted and scored in Likert fashion.

Note 2 A core of 22 individual items each with a 4-point ordinal response scale. In addition to questions relating to specific tasks, patients were asked to describe their degree of confidence in performing certain of the tasks. Four further questions were posed, asking patients to rate their general health status on a scale of 1 to 10. They were also asked to rate their overall distance vision, to rate their overall near vision, and to state agreement or disagreement with the statement, “I have to be more careful because of my eye condition.”

Note 3 Patient is asked to answer with range from “no difficulty at all” (1) to “stopped doing this because of eyesight” (5) or “because of other reasons” (6). There are two steps to scoring: original numeric values are re-coded according to a table (high scores represent better functioning). Each item is then converted to a 0 to 100 scale so that the lowest and highest possible scored are set at 0 and 100 points. In this format, scores represent the achieved percentage of the total possible score. Then items within each sub-scale are averaged together to create the 12 sub-scale scores (instructions are in a table to assign which items contribute to a specific sub-scale). Missing data items are not taken into account when calculating the scale scores. Scores represent the average for all items in the sub-scale that the respondent answered.

Note 4 Patient is asked “do you have any difficulty, even with glasses” for each question. “Not applicable” is scored as missing data, “no” receives 4 points to “yes, and am unable to do the activity” receiving 0 points. For the driving portion of the instrument, scores are “no difficulty” (4) to “great deal of difficulty (1). Items are not included for scoring if person does not do the activity for some reason other than vision. Scores on all activities performed or not performed because of vision are then averaged (resulting value 0 to 4), and that value is multiplied by 25, giving a final score from 0 to 100.

Note 5 Patients were asked two forms of questions: “How much has your eyesight interfered with … ?” was scored from “not at all” (0) to “can't do because of eyesight” (5), with an additional score for “don't do for other reasons” (8). Another question “In the past month, how often have you … because of eyesight?” was scored from “not at all” (0) to “a lot of the time” (5). All items were, accordingly, scored on a 0-5 scale (with responses of not applicable treated as missing). It is recommended that results be presented at the level of the item or at the overall scale, but not the subscale. Presumably, the overall scale score is obtained by multiplying the number of non-missing items by 10, although this is not explicitly stated.

## 3.2 QoL Instruments and Non-AMD Eye Diseases

Question 1b: Have these QoL measuring methods been used across other eye disease populations?

The SF-36 and its variants (the MOS-20 and SF-12) have been used across a variety of eye conditions as well as in several large studies of defined clinical populations, such as the Medical Outcomes Study and several NEI trials, and in population-based studies such as the Beaver Dam Health Outcomes Study.12,32-37 The QWB has also been used to assess impacts on patients and individuals with cataract surgery38 and in the Beaver Dam Health Outcomes Study.39 Literature searches targeting each of the other common global health-related QoL instruments – the SIP, EuroQol, and GHQ – with “vision” or “eye” revealed that no papers were published with the GHQ, five with the EuroQol (cataract surgery, diabetes eye disease, cytomegalovirus retinitis, and thyroid eye disease), and nine with the SIP (glaucoma, cataract surgery, and thyroid eye disease). In each study, the global measure was weakly, if at all, related to the presence of an eye disease and to changes in visual status. Interventions, particularly cataract surgery, were often associated with significant changes, but generally in the form of amelioration of declines in global functioning that would otherwise occur.12

The NEI-VFQ, ADVS, and the VF-14 have been utilized across other eye diseases that affect central vision (Table 2). The NEI-VFQ has been used more generally, as it was specifically designed as an instrument for evaluation of many eye diseases and patterns of vision loss.40 These instruments have generally been shown to vary significantly and appropriately in their scores relative to the severity of the eye condition in question, as measured by conventional measures which serve as proxies for functioning (e.g., visual acuity in cataracts) or by physiological measures of disease severity. Other diseases for which some version of the NEI-VFQ has been found responsive include glaucoma and its treatment, corneal diseases and surgery, diabetes and diabetes eye disease, retinitis pigmentosa, vascular occlusions in the retina, dry eyes, low vision services, optic neuritis, and several population-based studies and clinical trials.

Table 2 QoL instruments used in AMD patients and in other eye disease patient populations

Instrument | Cataract | Other macular diseases | Corneal diseases
ADVS | Mangione^12^1994 Mangione^43^1995 Pesudovs44 1998 Superstein45 1999 McGwin46 2003 Pesudovs47 2003 | None | None
NEI-VFQ | None | Tranos^48^2004 Tranos^35^2004 SSTRG^49^2005 | Kymes50 2004 Fink51 2005
VCM1 | Tinley52 2003 | None | None
DLTV | None | None | None
VF-14 | Steinberg53 1994 Steinberg54 1994 Damiano13 1995 Schein55 1995 Cassard56 1995 Desai57 1996 Alonso58 1997 Espallargues59 1998 Norregaard60 1998 Castells61 1999 Crabtree62 1999 Rose63 1999 Brydon64 2000 Lum65 2000 Lee32 2000 Lee33 2003 Norregaard66 2003 Mozaffarieh67 2004 Goyal68 2004 Aralikatti69 2004 Rosen38 2005 Mozaffarieh70 2005 Valderas71 2005 Lee72 2005 | Linder42 1999 | None

The VF-14 and ADVS were independently developed but share significant overlap of items, since each was designed for cataract evaluation for surgery. Therefore, they have been used more commonly in conditions that affect central vision, but have also been used in other diseases such as glaucoma. The ADVS has been used to assess not only cataract surgery and glaucoma but also giant cell arteritis (unable to differentiate those with and without visual loss).41

The VF-14 has been commonly used and is a popular instrument given its brevity and ease of administration, as well as its desirable psychometric properties. It has been tested and validated in patients with retinal disease including diabetic retinopathy. 42 It has also been validated in glaucoma, corneal transplants and keratoconus, dry eye patients, and those with nystagmus, low vision, after retinal detachment surgery.

The DLTV is a relatively newer instrument designed for AMD. As such, there have been no publications with the DLTV outside of the five papers assessing its performance in patients with AMD.

## 3.3 QoL Instruments and Psychometric Properties

Question 1c: What are the psychometric properties of these methods (e.g., reliability, validity, responsiveness, etc.)?

As noted previously, the impact of visual impairment potentially can be measured via patient-reported responses on instruments that are designed to capture visual functioning and the ability to complete vision-related tasks vision-related quality of life, as well as health status and quality of life in general. Psychometric properties of general health-related QoL measures such as the SF-36 and QWB are covered in considerable detail in other publications and are not included in this report, particularly since they have little if any relationship to the presence of eye diseases and changes in visual status associated with disease progression (see Section 3.1.2, “General Health-Related QoL Measures”). Similarly, the “vision-related” version of the SIP is not considered here, as this can primarily be considered to be a general QoL instrument. However, vision-specific QoL measures have consistently shown evidence of associations with AMD (and other eye diseases) and differences in visual status reflected in conventional measures of visual performance or physiological disease status. In addition, in studies of eye conditions they have demonstrated better discriminant validity and responsiveness than general QoL measures; for example, they were more responsive to efficacious interventions, such as cataract surgery, and better at distinguishing between the quality of life of groups with different degrees of visual impairment.43 Details of the psychometric property studies are provided in the evidence tables (Appendix B).

The review article by Margolis and colleagues73 provides an excellent overview of various methodological issues in the assessment of the psychometric properties of the instruments under consideration, and is particularly recommended. The review article by de Boer and colleagues74 provides similar information. The principal characteristics examined for the five vision-specific QoL instruments used in patients with AMD include the following:

Reliability is the consistency with which an instrument measures a given property or behavior.

Reliability includes internal consistency, reproducibility, and consistency of scaling.

- Internal consistency is the extent to which all items measure the same construct. It is primarily assessed using Cronbach's alpha, and is secondarily assessed using item-total correlation coefficients, as well as an assessment of floor and ceiling effects. For the VF-14, internal consistency was also assessed using the number of items that patients rated as applicable to their situation. During the preliminary development of a scale (often the item reduction phase), internal consistency may also be assessed using factor analysis.
- Reproducibility refers to the degree to which scores remain the same over time when the patient's true health status is unchanged. Reproducibility (also called test-retest reliability) is usually measured using an interclass correlation coefficient (ICC). Ideally, the assumption that the patient's true health status is unchanged will have been verified by direct observation or interview.
- Consistency of scaling refers to the degree to which x-unit differences in one part of the scale have a meaning similar to x-unit differences in another part of the scale (e.g., whether a difference between scores of 3 and 5 has the same substantive interpretation as a difference between scores of 40 and 42). Scaling consistency is often measured using techniques of Rasch analysis and item response theory. Note that scaling consistency could reasonably be categorized separately.

Validity is the extent to which an instrument measures what it purports to measure. It can be expressed in several ways.

- Content validity is the degree to which an instrument measures what it purports to assess – in this case, what is important to patients, clinicians, and other interested parties. The assessment of content validity is qualitative, in large part depending upon the quality of the processes used during instrument development. We comment on content validity only for instruments that have demonstrated good psychometric properties otherwise.
- Construct validity evaluates how well a measure correlates with other indicators of similar and related constructs. In this application, such constructs often include objective measures of visual function, general health measures, and self-reported global items about quality of vision, satisfaction with vision, and the like. Construct validity can be further subdivided into convergent validity and discriminant validity, the former assessing the degree to which an instrument correlates with other measures of the same or similar constructs, and the latter assessing the degree to which the measure can discriminate between cases and controls, disease severity groups, or other groups that are expected to have different levels of vision-related quality of life. Construct validity is typically measured by considering correlations and patterns between group means. The magnitude of differences between group means is sometimes quantified using effect sizes.

Responsiveness refers to the extent that an instrument can detect change in patients that are known to have a change in their underlying state of interest – in this case, their visual functioning and vision-related abilities or limitations to pursue or enjoy activities that cam be affected in some way by their vision. Responsiveness is usually assessed by comparing mean scores before and after an intervention (ideally, using difference scores calculated within a subject). The magnitude of differences between group means is sometimes quantified using effect sizes, particularly where scale scores are arranged on a numeric scale.

The above psychometric properties have been summarized in evidence tables for this report (Appendix B). Those instruments that have demonstrated particularly good psychometric properties in an extensive validation are also discussed in a more detailed summary below. Where instruments have been developed in both English and non-English versions our emphasis is on the version in English. The impact of different languages and the cultural milieu are discussed below in reference to Question 2 (Section 3.4).

Where substantial efforts at instrument validation have been applied to patients with AMD, we focus on these efforts. Where relatively fewer validation efforts specific to patients with AMD are available, our focus extends beyond AMD to include other vision-related conditions. Note that studies in which quality of life is compared with measures of visual loss are discussed under Question 3.

It is important to recognize that there is no consensus on benchmarks for strength of conformance with psychometric criteria. Accordingly, adjectives corresponding to these criteria are qualitative. The work of Lamping et al.75 provides an example of a typical set of benchmarks.

### 3.3.1 VF-14

The VF-14 was originally developed by Steinberg et al.53 as an index of visual function in patients undergoing cataract surgery. Briefly, respondents are first asked whether they have any difficulty with various vision-related tasks (e.g., reading, even with glasses, a newspaper or a book). A category of “not applicable” is included. If the answer to the lead-in question is affirmative, the level of difficulty is placed on a 4-point scale (1 = a little, 2 = a moderate amount, 3 = a great deal, 4 = unable to perform activity). Scores for applicable items are averaged, then inflated to a 0 to 100 scale. Initial development included patient interviews. Most validation has taken place within the context of cataract surgery, but studies by Linder42 and others included patients with AMD.

Internal consistency: Cronbach's alpha was high in the two studies pertaining to AMD; for example, 0.91 in Linder.42 These figures were representative of the other studies and within the benchmarks typically recommended for an excellent instrument.

The remaining data on internal consistency pertains to patients undergoing cataract surgery. Item-total correlations were relatively modest, ranging from approximately 0.3 to 0.7, and were below benchmarks. Alonso58 found that few patients believed all 14 items to be relevant, although Steinberg53 found the median number of relevant items to be 12. Accordingly, most patients found most items to be relevant, which is probably all that is reasonably required. A factor analysis by Steinberg supported the notion that the 14 items comprise a single scale.

Reproducibility: There is no information available regarding reproducibility for English versions of the instrument. In a small study using the French version of the instrument,76 the ICC was an encouragingly high value of 0.88.

Scaling consistency: Application of Rasch analysis to the VF-14 demonstrates reasonable interval scaling, though the scale as a whole may be able to be shortened to provide even greater efficiency in capturing data relative to cataract surgery.77 Overall, these results support the conclusion that the instrument is internally consistent.

Construct validity: The evidence in favor of construct validity was consistent. Correlations with self-reported global items (trouble with vision, satisfaction with vision, quality of vision) were moderately strong (usually in the range of 0.4 to 0.6), and were higher than similar correlations between generic instruments and these same global items. There was a strong relationship between AMD severity and VF-14 total score.22

Responsiveness: The instrument is responsive to an intervention whose effectiveness is on the order of magnitude of cataract surgery. Alonso's estimate of an effect size of approximately 1 is representative.58 No information about responsiveness is available from patients with AMD.

Overall: Among patients undergoing cataract surgery, although the item-total correlations for the scale were only moderate, the content validity and responsiveness of the instrument was solid, and thus the overall evidence for the validity of the VF-14 is strong. The evidence for the validity of the VF-14 in patients with AMD is less strong due to the limited number of studies in AMD with this instrument, although the consistency of the cross-sectional results provided by Linder42 and MacKenzie22 (which included AMD patients) and the cross-sectional validation results in patients undergoing cataract surgery is encouraging. It has not yet been demonstrated that the VF-14 is responsive to changes that would be attributable to AMD-specific interventions, particularly after adjustment for visual acuity.

This summary was based on evidence tables for those studies that included patients with AMD, namely Linder,42 Sharma,78 Riusala,79 Armbrecht,80and Mackenzie;22 evidence tables for two large studies in patients undergoing cataract surgery, namely Alonso58 and Steinberg;53 and various smaller studies in patients undergoing cataract surgery that provided substantively similar conclusions, namely Velozo,77 Javitt,81 Cassard,56 Tielsch,82 Desai,57 Armbrecht,83 Castells,61 Nijkamp,84 and Gresset.76

### 3.3.2 NEI-VFQ

A list of the items included in the NEI-VFQ is provided by Mangione and colleagues,85 who give this description: “This measure includes multi-item scales to rate overall health on a 5-level scale that ranges from excellent to blind; multi-item scales that assess difficulty with near vision activities, difficulty with distance vision activities, limitations in social functioning due to vision, role limitations due to vision, dependency on others due to vision, mental health symptoms due to vision, future expectations for vision, driving difficulties, and pain and discomfort in or around the eyes; and single items to assess limitations with peripheral vision and color vision.” Items were developed from patient focus groups representing a diverse set of visual conditions,86 the intention being to develop a scale that can be generalized to all patients with vision deficits, regardless of cause. (Indeed, subgroup analyses performed during the validation of the initial NEI-VFQ-51 that presented the data by cause of visual deficit supported the conclusion that the scale could, in fact, be generalized in this way.) The content validity of this instrument is high.

The NEI-VFQ is noteworthy in that it has been validated in populations of patients with a diverse set of eye diseases. The initial validation was performed on a 51-item version of the form (NEI-VFQ-51). It should be noted that even in this long version most subscales have few items, which will tend to degrade measures such as Cronbach's alpha (which increases with the number of increasing items.) In any event, the largest validation study for the NEI-VFQ-51 had 583 patients. Attention then shifted to creating shorter versions of the instrument. The 39-item version of the form had a validation study with over 4,000 patients, and the 37-item version can be considered to be functionally equivalent to the version with 39 items (2 items were dropped, and the other 37 items retained as is). One of the studies of the 37-item version of the form noted that subscale scores for the NEI-VFQ-25 were similar to those of the NEI-VFQ-37, and concluded that the 25-item version of the instrument was likely to exhibit similar performance in practice. The 25-item version of the instrument has been used in several large validation studies, for example, with sample sizes 4,119; 1,052; and 859.

It appears that, in practice, the version of the instrument that is most likely to be used is the NEI-VFQ-25. Accordingly, the following summary focuses on the 25-item version of the instrument. The psychometric properties of the 51-, 39-, 37- and 25-item versions of the instrument appear similar.

Internal consistency: Cronbach's alpha coefficients ranged from 0.47^87^ to 0.81 when calculated at the level of the subscale, but were high (e.g., 0.92) when calculated for the total 25-item scale. Although certain subscales exhibit floor and ceiling effects, the overall score does not.

Reproducibility: Reproducibility was reasonable, with test-retest ICCs ranging from 0.68 to 0.91.^85^ Lowest performance was for the driving scales, perhaps reflective of the diverse nature of the older population in driving, the difficulties of attribution of limitations in driving in this population, and the impact of other comorbid ocular or systemic diseases on driving.

Scaling consistency: Rasch analysis in patients with low vision administered the NEI-VFQ demonstrated that those items that deal with difficulty in performing tasks scale with good intervals between and among responses. However, as might be expected, those items that refer to frequency or level of agreement with a statement (typically patient perceptions) did not scale with intervals.88

Construct validity: The evidence in favor of construct validity, such as Clemons,89 was consistently strong. For example, high correlations were reported with visual function, the instrument successfully classified patients according to disease severity, and the pattern of correlations among the subscales was as anticipated.

Responsiveness: Although perhaps not as extensive as the evidence in favor of construct validity, the evidence in favor of responsiveness was solid. Scale scores tended to improve with intervention, and greater improvement in visual function was associated with greater improvement in the NEI-VFQ. While not responsive in every study, several studies demonstrated differences in NEI-VFQ scores even after adjustment for visual acuity. Further, across the range of developmental conditions (cataract, glaucoma, AMD, and diabetic retinopathy), as well as other conditions as diverse as corneal diseases and vascular occlusions of the retina, NEI-VFQ scores vary in the expected direction with differences in visual performance and disease state.

Overall: This scale exhibits excellent validity across a wide variety of patient groups, including those with AMD. The 25-item version of the scale performs similarly to longer versions. The reader is referred to the evidence tables (Appendix B) for additional details for studies including those by Massof,88 Mangione,85 Tranos,48 Clemons,89 Berdeaux,90 Miskala,91 Miskala,92 Miskala25 Lindblad,6 CAPT, 87 Mangione,40 Brody,93 Cahill,29 Cahill,28 Scilley,94 Childs,24 Dong,23and Tranos.35

### 3.3.3 ADVS

Internal consistency: One small study95 reported evidence of the presence of strong ceiling effects. Otherwise, little information is available regarding the internal consistency of this scale.

Reproducibility: No information is available about the reproducibility of this scale.

Scaling consistency: Rasch analysis indicated that many of the items did not scale at equal intervals for cataract evaluation and cataract surgery.47

Construct validity: One large study96 provided some evidence of construct validity, and in another smaller study,97 both the ADVS subscales and overall scale correlated with scotopic sensitivity. However, the ADVS did not correlate highly with stage of AMD severity after correction for visual acuity.86

Responsiveness: Patients with cataract demonstrated good reliability and responsiveness of the ADVS pre- and post-cataract surgery.86

Overall: Although potentially promising, the ADVS has not been submitted to as extensive a validation as either the VF-14 or the NEI-VFQ. Further, unlike the VF-14 and NEI-VFQ, Rasch analysis has demonstrated areas of unequal scaling.

### 3.3.4 VCM1

This 10-item instrument is targeted toward vision-related patient perception of quality of life, the items including embarrassment, anger, depression, loneliness, fear of deterioration in vision, safety at home, safety outside the home, coping with everyday life, inability to do preferred activities, and life-interference, as related to patients' visual status. Initial development of the instrument was based on interviews with patients and providers,98 and the content validity is good.

Internal consistency: The 10 items appear to load onto a single scale, with good internal consistency (Cronbach's alpha 0.93, item-total correlations 0.65 to 0.79).

Reproducibility: Reproducibility is good, with an ICC of 0.90.

Scaling consistency: No information is available regarding scaling consistency.

Construct validity: In a large study VCM1 scores were correlated with age and social class, and in a smaller study VCM1 scores were highly correlated with the VF-14 and moderately correlated with objective measures of visual function.

Responsiveness: Except perhaps for the results of a single trial that reports change between baseline and 12 months, but does not relate this change to other measures of vision,26 no information is available regarding responsiveness.

Overall: Validation efforts to date, although not as extensive as those for the VF-14 or NEI-VFQ, have produced promising results regarding internal consistency, reproducibility, and construct validity. No information is available regarding scaling or responsiveness.

### 3.3.5 DLTV

The DLTV was developed specifically for patients with AMD, began with patient focus groups, and has reasonable content validity. The complete 24-item instrument is provided by Hart.99 Most items, all of which have four response categories, pertain to difficulty with tasks, two items pertain to confidence, and items are general.

Internal consistency: Factor analysis supports the distribution of items into subscales, and Cronbach's alphas for the dimensions range from 0.66 to 0.96. The internal consistency is reasonable to good.

Reproducibility: No data are available regarding reproducibility.

Scaling consistency: No data are available regarding scaling consistency.

Construct validity: Although not comprehensive, the information to date (mostly correlations with objective measures of visual acuity) supports the construct validity of the scale.

Responsiveness: No information is available regarding responsiveness.

Overall: Validation efforts to date, although not as extensive as those for the VF-14 or NEI-VFQ, have produced promising results regarding internal consistency and construct validity. Future investigation may be helpful in determining the level of usefulness of the DLTV. No information is available regarding reproducibility, scaling consistency, or responsiveness.

### 3.3.6 Summary

The psychometric properties of the vision-specific instruments described above are summarized in Table 3.

Table 3 Summary of psychometric properties for vision-specific instruments (details in evidence tables in Appendix B)

Property | VF-14^22,42,53,56-58,61,76-84^ | NEI-VFQ6,23-25,28,29,35,40,48,85,87-94 | ADVS47,86,95-97 | VCM1^26,98^ | DLTV27,99-102
Internal consistency | ++ | +/++ | 0 | +/++ | +/++
Reproducibility | 0 | + | NA | + | NA
Scaling consistency | +/0 | +/0 | +/0 | NA | +/0
Construct validity | ++ | ++ | + | + | +
Responsiveness | + | + | + | NA | NA

NA = psychometric property was not assessed; 0 = assessed but little or no evidence in favor of this psychometric property; + = moderate evidence in favor of this psychometric property; ++ = strong evidence in favor of this psychometric property

## 3.4 QoL Instruments and Other Factors

Question 2: What are other factors that may influence responses using these methods?

When patients are asked to report their functioning, several factors can potentially influence how they respond other than their visual status alone. There are several studies that specifically address factors that influence responses on vision-specific QoL questionnaires in AMD patients.

These factors can center on the patient and their reactions to their disease, the presence of co-morbid systemic diseases and conditions, and the methods of measurement themselves.

First, patients may suffer significant emotional distress, depression, or fear upon an initial diagnosis of an eye disease, such that those factors color their reported perceptions of their abilities to function. Williams et al. examined this question in AMD patients with legal blindness in at least one eye using global health-related QoL measures along with the Profile of Mood States.30 They correlated a shorter period of perceived vision loss with increased likelihood to report high levels of emotional distress and lower quality of life. Furthermore, those who were blind in one eye were even more significantly distressed than those who were blind in both eyes, as they feared vision loss in their unaffected eye. Thus, this study established both a time component from the time of diagnosis and a significant effect of mental and emotional states on QoL scores. This is reinforced by other studies establishing a significant incidence of depression in patients with AMD.103 The same phenomenon is present in patients upon initial diagnosis in other diseases, such as glaucoma.104 Because of this, and for simplicity and reliability, almost all developmental papers for vision-specific QoL instruments such as the NEI-VFQ include only those patients who have a stable disease state and were diagnosed for at least 3 to 4 months to maximize reliability and stability of responses.

Second, Owsley and McGwin105 demonstrated that older persons who are depressed may have reduced scores on the NEI-VFQ-25 independent of the impact of vision problems. Similar findings were reported by Lee et al. in analyses of the SF-36 results from younger cohorts in the Medical Outcomes Study relative to visual symptoms and difficulty seeing, even inclusive of other medical and systemic symptoms.5 Thus, not only may AMD cause depression, but those who are depressed may score lower on the NEI-VFQ summary scores and on scores for distance vision, peripheral vision, vision-specific role difficulties, vision-specific dependency, and vision-specific mental health.105 Of note, however, depression due to AMD can be ameliorated over 6 months by a self-management treatment strategy, but only for those who were initially depressed and not for those without depression, such that NEI-VFQ scores can rise in that subgroup with initial depression.93 Patients who are informed of a serious illness or condition often become depressed for various time intervals, as exemplified by Kubler-Ross's five stages of grief.

Third, Miskala et al. hypothesized that a vision-specific instrument would be influenced by general health.91,106 They examined the responses of 120 patients with advanced AMD in at least one eye to the NEI-VFQ and the SF-36. They correlated large decreases in the physical and/or mental components of the SF-36 with more modest decreases in the NEI-VFQ. Therefore, the authors recommended adjustment for general health when comparing NEI-VFQ scores across patient groups, suggesting that the SF-36 scores could act as such an adjustment factor.

Fourth, Frost et al. demonstrated that among an elderly population in the UK, vision-specific QoL impairment as measured by the VCM1 increased as age increased, social class decreased, and material deprivation increased, while sex and means of administration were not associated.107 While it is likely that the prevalence of significant untreated ocular conditions that would impact upon VCM1 scores would increase in the lower socioeconomic strata, this does suggest the need for additional study to elucidate the causes of this finding. Of note, similar findings related to conventional measures of visual performance, such as visual acuity and legal blindness and socioeconomic status, were found in the Baltimore Eye Study in the United States.108

Fifth, while several translations have been made of the NEI-VFQ (French, Italian, Spanish, Turkish, and many other languages) and have been found to have acceptable psychometric properties in the translated languages for patients with eye diseases (which may be a testimony more to the methods of translation than the instrument itself), Varma et al. in the Los Angeles Latino Eye Study demonstrated that a normal patient's native or preferred language (Spanish or English) has an independent association with the NEI-VFQ scores and psychometric properties.109 Whether this holds for patients with AMD or other ocular diseases is unknown, but there is no reason to suspect that this difference would not persist. Thus, in ethnically and linguistically diverse populations, recognition that mean scores could vary based on whether an English or Spanish version is administered should be included in data analyses with instruments administered in more than one language.

Finally, standard psychometric considerations such as order of instrument administration have been assessed for some of the NIH/NEI Trials, such as the Submacular Surgery Trials Group.110 Related issues such as mode of administration (face-to-face, phone, self-administered) and timing of administration during an interaction or afterwards likely behave similarly to other disease- or condition-specific instruments.111

## 3.5 QoL Instruments and Outcome Measures

Question 3: How do these QoL measurement methods relate to traditional outcome measures (e.g., visual acuity, contrast, etc.)?

We examined the relationship of QoL measurement methods to traditional outcome measures in the context of the instrument and the type of study (observational versus interventional). This allows us to evaluate the performance of various instruments as a direct correlation to the objective measures, and to test the instrument's responsiveness, or sensitivity to change over time.

### 3.5.1 NEI-VFQ

The NEI-VFQ has been extensively utilized in several studies of AMD. It has been introduced by the NEI into NEI-sponsored clinical trials, which has generated significant amounts of NEI-VFQ data.

#### 3.5.1.1 Observational Studies

The study by Scilley et al. examined the NEI-VFQ results of a population of AMD patients seeking low-vision services.94 They compared their population to other AMD patients and non-AMD patients seeking low-vision services. They found lower scores on the overall score and the near vision, distance vision, social functioning, and other subscales as compared to the control patients with similar levels of visual acuity. They concluded that AMD patients seeking low-vision services have decreased vision-specific QoL scores for their given visual acuity as compared to the control populations.

The other cross-sectional studies employing the NEI-VFQ in AMD were carried out in the enrollment phase of several interventional trials. The NEI's Age-Related Eye Disease Study was a large multicenter study designed to evaluate the effect of antioxidant vitamins and zinc on progression of early AMD. Investigators attempted to correlate NEI-VFQ scores with clinical measures of visual function.89 They found lower scores in participants with advanced AMD in one or both eyes as compared with disease-free participants.

Another NEI trial investigating the effect of sub-threshold laser treatment of the macula in early AMD (Complications of Age-Related Macular Degeneration Prevention Trial) also performed a cross-sectional analysis of enrolled patients.87 In this study, investigators found only a weak association between NEI-VFQ scores and measures of visual function, and no association with fundus features of clinical severity. This might have been due, in part, to the relatively homogeneous group of participants and variety of responses.

Another study obtained visual acuity and QoL measures on patients with late AMD enrolled in a trial investigating the outcome of submacular surgery on AMD (Submacular Surgery Trial).23 These investigators established a strong association between visual acuity in the better eye with the NEI-VFQ scores but not with other global QoL measures (scores on the SF-36 and Hospital Anxiety and Depression Scale [HADS]). Furthermore, patients with bilateral disease scored six to 10 points lower than those with unilateral disease. Therefore, there was a more specific correlation of visual function with a vision-specific instrument, and the vision-specific instrument was impacted by bilaterality of disease. These correlations, while strong, remain only moderate (0.2 to 0.4 in general), suggesting that visual acuity and the results with the NEI-VFQ are complementary in nature. Further, from a clinical perspective, the history of eyes with AMD is unpredictable, such that what is the worst eye may become the better eye for patients in the future.

The study by Berdeaux examined the correlation of the best eye's visual acuity and the worst eye's visual acuity with the NEI-VFQ.90 Investigators enrolled patients about to undergo photodynamic therapy with verteporfin for late AMD. They found a strong association of the NEI-VFQ with the best eye's visual acuity and a weaker, yet still significant association with the worst eye's visual acuity. They concluded that even preserving vision in the worst eye may have an impact on vision-related quality of life.

Another study was drawn from the baseline characteristics of patients enrolled in a surgical trial for late AMD (macular translocation with 360° peripheral retinectomy).29 Investigators found a positive correlation of NEI-VFQ with visual acuity and reading speed. Unlike the other patient populations, these were patients with uniformly bilateral late disease. Therefore, the population is more homogeneously affected than in prior studies.

#### 3.5.1.2 Interventional Studies

The Submacular Surgery Trials Study Group published two papers on the results of submacular surgery on two types of advanced AMD (Group N, primarily neovascular, and Group B, primarily hemorrhagic subfoveal neovascularization).24,25 In these trials there was a positive and significant relationship between visual acuity and NEI-VFQ scores. Although there was no significant change in the final visual acuity between the treated and observation arms of the studies, patients with different levels of visual acuity had different NEI-VFQ scores. Similarly, there was no significant difference in the NEI-VFQ results between the different arms in both studies.

Three studies demonstrate responsiveness of the NEI-VFQ. The first is the AREDS Research Group's results in the patients that had progression of AMD with vision loss.6 The NEI-VFQ score was responsive to AMD progression and vision decrease (p < 0.001 for each). A 15-letter visual acuity loss and progression to advanced AMD correlated with a decrease in overall NEI-VFQ score and changes of subscale scores of 10 points or more.

The study by Cahill demonstrated similar responsiveness of the NEI-VFQ.28 However, in this study there was responsiveness to a significant increase in visual acuity in AMD. Investigators studied 50 patients who underwent macular translocation surgery for advanced AMD. The patients had a significant improvement in near visual acuity and reading speed, and a trend toward improvement in distance visual acuity. There was a corresponding increase in the composite NEI-VFQ score by 10 points and significant increases in many of the subscales. This study therefore demonstrated positive responsiveness of this vision-specific QoL instrument as a result of an intervention.

Brody et al.93 used the NEI-VFQ as a secondary outcome measure in a trial of a self-management intervention aimed at primarily improving mood. While the primary outcome measure (Profile of Mood States) indicated some improvement, there were marginal changes in the NEI-VFQ. The lack of responsiveness may more reflect the nature of the intervention than the responsiveness of the NEI-VFQ to changes in vision-related quality of life.

In summary, the NEI-VFQ is a vision-specific QoL instrument that has been evaluated in observational studies and numerous NEI-sponsored trials for AMD. It has demonstrated correlation with visual acuity and reading speed in these patients.

### 3.5.2 VF-14

The VF-14 was developed through funding by the Agency for Healthcare Research and Quality (AHRQ; formerly the Agency for Health Care Policy and Research [AHCPR]) to investigate QoL issues in patients with cataract and cataract surgery. The utility of the VF-14 instrument for AMD was examined in two observational studies and one interventional study in AMD. The study by MacKenzie22 investigated the validity of the VF-14 in assessing visual function in patients with early and late AMD. Investigators found the instrument to have a stronger correlation with visual functional impairment than with visual acuity or AMD severity.

Riusala et al. studied the value of the VF-14 in patients with long-standing late AMD.79 They found that the VF-14 correlated significantly with best-corrected visual acuity, contrast sensitivity, and global assessment scores of satisfaction with vision and quality of vision. Again, as in the previous study, the correlation of the VF-14 was stronger with global assessment scores than the VF-14 relative to other conventional objective measures. Therefore, investigators concluded that this instrument reflected a more complete assessment of the individual's function that objective measures alone.

The study by Armbrecht et al. evaluated the VF-14 in the context of a photodynamic therapy, a therapeutic intervention for late AMD.80 Generally, this therapy reduces severity of vision loss in late AMD. All the patients in this study received the intervention, so no control group was available for comparison. Seventy-one percent of patients lost less than three lines of best-corrected visual acuity at distance, and these results were consistent with the observed visual acuity results with this treatment. The VF-14 showed significant decreases in the total score and in select items that correlated with the decrease in visual acuity and contrast sensitivity, and an increase in AMD lesion size.

In summary, the VF-14 instrument demonstrated a general correlation with visual acuity and contrast sensitivity in two non-interventional studies. An interventional study in which the expected outcomes were a decrease in visual acuity, decrease in contrast sensitivity, and increase in lesion size demonstrated a commensurate decrease in the overall VF-14 score, as well as in related subscales. Thus, there is a limited database to evaluate the adequacy of the VF-14 in AMD, though these studies demonstrate good performance.

### 3.5.3 ADVS

Scilley performed a comparative, cross-sectional study of patients with early AMD and relatively good vision with age-matched patients with good vision.97 The major finding in this study was that there was a significant difference in the night driving, near vision, and glare disability in the AMD patients compared to the control patients.

Mangione et al. performed a cross-sectional, observational cohort sample of 201 patients with various stages of AMD.21 Investigators correlated poorer ADVS scores with increased clinical severity of AMD. Of note, once visual acuity was taken into consideration, the clinical grading of maculopathy did not explain variations in visual functioning. Therefore, it appears that in these two observational studies, there was not a great correlation between visual acuity and the ADVS.

### 3.5.4 Summary

In summary (Table 4), it may be reasonable to conclude from the available data that the NEI-VFQ has demonstrated correlation with the traditional outcome measures of visual acuity, contrast sensitivity, and reading speed. It is also the only instrument that has demonstrated responsiveness. The VF-14 has been demonstrated to correlate with some traditional outcome measures, but there are limited data available.

Table 4 QoL instruments used in AMD patients and correlation with objective measures^*^

Instrument | Visual acuity | Contrast sensitivity | Reading speed | Clinical severity
ADVS | Mangione^21^1999 +/+/- Scilley97 2002 +/+/- | | | Mangione21 1999 +/+/-
NEI-VFQ | Clemons89 2003 +/+/+ Scilley94 2004 +/0/- CAPT87 2004 +/+/+ SST23 2004 +/+/+ SST24 2004 +/+/+ SST25 2004 +/+/+ Berdeaux90 2004 +/0/+ Cahill29 2005 +/+/- Cahill28 2005 +/+/- Brody93 2005 +/0/- AREDS6 2005 +/+/+ | CAPT87 2004 +/+/+ | CAPT87 2004 +/+/+ Cahill28 2005 +/+/- | AREDS6 2005 +/+/+
VCM1 | Reeves26 2004 +/+/-
DLTV | Hart99 1999 +/+/+ McClure102 2000+/+/+ Stevenson101 2003 +/+/+ Stevenson27 2005 +/+/+ | | McClure102 2000+/+/+ | Stevenson27 2005 +/+/+
VF-14 | MacKenzie22 2002 +/0/- Riusala79 2003 +/0/- Armbrecht80 2005 +/0/- | | None | MacKenzie22 2002 +/0/-

* Bold denotes strong association with measured objective parameters; associated quality criteria denoted with +, 0, or - for “study population defined in meaningful way” / “instrument administered unbiased” / “statistical power or size specified”

## 3.6 Utility Assessment in AMD

The measures described above are of health states and values. Health states are general health conditions or particular dimensions of health, such as physical functioning, pain, and depression. Health preference relates to the desirability of a health state relative to other health states or disease outcomes. If the preference measurement question is asked under a condition of certainty, then a preference value is being ascertained (examples being the Time Trade-Off [TTO] or Rank and Scale [RS] techniques). If risk or uncertainty is incorporated into the preference measurement question, then utility is being assessed (an example being the Standard Gamble [SG] technique). While the SG is desirable as being consistent with the axioms of utility theory, it is perceived to be difficult to understand and to administer (since some people are troubled in some way by the exercise requiring considering gambles that may lead to death), and thus the value technique of TTO is more often used as a utility surrogate.

Although not strictly speaking a health-related QoL measure, utility assessment is advocated as a way to establish an approximate equivalence between benefits in disparate health domains. Moreover, utility assessments can be used in calculating incremental cost-effectiveness ratios, a metric that can provide a rationale for allocating health resources.

In AMD, we identified two research groups that published their experience with utility assessment.78,112-119 The original work by Brown112 is representative. He noted that TTO is more palatable to patients than SG. The results did not correlate with visual acuity in the worse eye, but correlated moderately well with visual acuity in the better eye (r^2^ = 0.23), and the response was not affected by age, level of education, sex, race, length of time of visual loss, cause of visual loss (predominantly diabetic retinopathy), or other comorbidities. However, experience with these measures in visual disorders is limited; in addition to studies of relatively few (and apparently often overlapping) subjects, we did not identify any clinical trials in AMD in which utility assessment was directly used in comparing treatment alternatives. Further, the two research groups obtained different values for the same level of visual acuity (69, 112-119).

Utility analyses have been conducted with other eye diseases in various contexts, particularly around the area of cataracts and cataract surgery in many different countries. In these studies, impaired vision was found to be significantly related to reduced utility scores, especially with the use of TTO when it was feasible. Since utility assessment is of potential value in a policy context, further work in this area is appropriate, being cognizant of the limitations present in utility analyses.120