# Methods

## 2.1 Overview

The methodological approach to this review was designed to support the Medicare Coverage Advisory Committee (MCAC) deliberations regarding whether specific health-related QoL methods or instruments provide meaningful information about outcomes in individuals with AMD and similar disorders, and the degree to which these instruments are scientifically credible (e.g., have good psychometric properties, including convergent validity when compared to objective visual assessments.) The goal was to provide the most direct responses possible to the key questions listed above. In particular, we sought to highlight literature that would be of greatest value for the purpose at hand, focusing on articles and studies that describe instruments used in sizable populations with well-characterized AMD (and related eye diseases that affect central vision).

## 2.2 Search Strategy

We searched MEDLINE from 1966 to September 2005 using a search strategy (detailed in Appendix A) that combined the two concepts “age-related macular degeneration” and “quality of life.” The objective was to identify all studies that provided primary data regarding health-related quality of life among individuals with AMD and related conditions. For purposes of this review, related conditions included eye disorders that could lead to central visual loss, specifically diabetic macular edema, macular hole, cataracts, keratoconus, and corneal scarring. Diseases known to primarily affect vision other than central vision, such as glaucoma (with its impact being primarily visual field loss until late in the disease) were excluded from the primary analyses.

To identify the disease concept, we also used MeSH headings “macular degeneration,” “retinal degeneration,” “retinal diseases,” and “vision disorders (exploded).” We also used text word searching for the text string “vis$ adjacent to funct$”; this is designed to detect various spellings such as “visual function” or “visual functioning.” Finally, the two concepts were combined (Boolean “and”). The strategy was limited to articles published in the English language.

Additionally, we searched for reports by authors known to publish in this area, as well as articles uncovered by reviewing the bibliographies of review articles discovered in our search and studies that satisfied inclusion criteria. We also supplemented the search by performing additional literature searches with the names of the specific instruments e.g., “name of specific instrument” AND “vision” and “name of specific instrument” AND “eye” once they had been identified as having been used in AMD. Once the set of included instruments was finalized, we used similar methods to search for all applications of these instruments to patients with eye disease.

## 2.3 Inclusion Criteria

Articles were included if the study population had the diagnosis of AMD, were 18 years of age and older, and the sample included 10 or more subjects. In addition, we included articles regarding instruments or methods that were used in study subjects with other eye disorders where the instrument had also been used in some included study of AMD patients. For studies of psychometric properties, we included any study that assessed reliability (internal consistency, test-retest), validity (content, construct, concurrent, and discriminant), or responsiveness.

## 2.4 Abstraction

Articles were abstracted directly into evidence tables (Appendix B). The elements included in the abstraction were as follows:

Identifying information
- First author (last name, first initial)
- ProCite number

Study characteristics
- Country
- Year
- Context (e.g. clinical trial, cohort, cross-sectional study)
- Inclusion/exclusion criteria

Subject characteristics
- Number of subjects
- Age
- AMD %
- AMD type (% wet/% dry)
- Laterality (unilateral/bilateral)
- Other eye disease %
- Objective measure(s) of function, (e.g., visual acuity)

Instrument characteristics
- Instrument name
- How administered
- By whom (masked/unmasked)
- Mode of administration (phone, face-to-face, mail in, in office, observation)
- Respondent (patient only, patient or surrogate, surrogate only)
- Time points of administration (pre-/post-surgery)

Quality characteristics (see Appendix C for quality criteria)
- Meaningfully defined study population
- Protection from bias
- Consideration of statistical power

## 2.5 Summarizing Results

We approached the summarization of the literature by key questions:

- Question 1a: Results are listed by instrument for AMD and related patients.
- Question 1b: Same as Question 1a, but for non-AMD patients, using instruments and methods used in Question 1a.
- Question 1c: Psychometric properties (validity [content, construct, concurrent, discriminant], reliability [internal consistency, test-retest], and responsiveness).
- Question 2: Factors identified as affecting scores on instruments or methods measuring the impact of AMD on patients.
- Question 3: Relationship between QoL measure(s) and objective measure(s).

Note that for the sake of completeness, we also examined studies of direct utility measures. Since these policy-relevant measures are distinct from QoL measures, they are summarized under a separate heading within Section 3 (“Results”).

## 2.6 Quality Criteria

In the absence of an established quality measure for health-related QoL instruments (other than the standard psychometric property criteria noted above), we assessed three characteristics deemed important in such studies (see Appendix C). First, we considered whether the study population was defined in a clinically meaningful way. To assess this, we noted whether the study quantified characteristics that were crucial to the interpretation of study results (e.g., the proportion of patients with AMD, and type of AMD [at least wet vs. dry, since the visual status and prognosis are significantly divergent between these two clinical forms]). Second, we assessed whether the study made an explicit effort to protect from bias. Here we focused on whether the individual responsible for the assessment was identified and had a stake in the result (e.g., the surgeon or assistant). Third, we noted if statistical power or sample size was specified as it related to analyses of interest. As an approximate rule of thumb, analyses with fewer than 100 subjects tend to have less ability to detect small(er) differences, analyses with 100 to 400 subjects tend to have a greater ability to do so, and analyses with more than 400 subjects tend to have the ability to find significance with small differences. As with other inquiries, the power and associated sample size issues should reflect the endpoint of interest, whether this is treatment effect as measured by visual acuity or by responses to a vision-related QoL instrument. Related statistical issues arise when the variance in responses to a measure is greater or less than the variance in responses to other measures.