# Overview of Age-Related Macular Degeneration

Age-related macular degeneration (AMD) is a degenerative retinal disease that affects the central retina, or macula. It is the leading cause of irreversible visual loss and legal blindness in persons over 50 years of age in industrialized countries. AMD affects approximately 15 million people in the United States alone, and current estimates project this figure to increase by 50% by the year 2020.^1,2^ AMD will affect over one quarter of those in a representative cohort in the Medicare program who survive at least 9 years.3

There are two major clinical forms of the disease, “wet” and “dry.” The “dry” form initially consists of abnormalities in the retinal pigment epithelium and other layers of the internal structure of the eye (“drusen”). It can then worsen to more advanced forms of dry AMD, as evidenced by larger areas of confluent drusen formation (“soft drusen”), secondary pigmentary changes, and atrophy of large areas of the retinal pigment epithelium (“geographic atrophy”). This early dry phase may convert to the more severe “wet” form of the disease in 10 to 20% of patients. Wet AMD (“neovascular”) is characterized by the development of abnormal blood vessels underneath the retina in the macular region, which subsequently bleed and then heal via normal mechanisms, resulting in scar tissue formation and the destruction of the overlying retinal layers responsible for sensing light. Approximately 1.75 million Americans (10% of those with AMD) have the advanced or late forms of the disease (wet AMD or geographic atrophy).4

AMD can have a devastating impact on many of the basic activities and intermediate activities of daily living such as driving, recognizing faces, dressing, self-care, and reading. Since the disease affects the elderly population, it robs many individuals in their retirement years of their independence and may compound the effects of other chronic diseases. As such, blindness from causes such as AMD has traditionally been one of the three leading fears of Americans, after cancer and AIDS/HIV.5

Fortunately, several therapies are now available to combat the progression of the most severe forms of macular degeneration, particularly the wet form. Investigators have shown in the Age-Related Eye Disease Study (AREDS) that the progression from the severe dry form to the wet stage can be reduced by about 25% with the use of daily antioxidant vitamins with zinc supplements compared to placebo controls.6 Once patients have the wet form, several therapies have been shown in randomized controlled trials to reduce the degree of associated visual loss compared to the natural history of the disease among controls without treatment, including standard argon laser;7 photodynamic therapy combining intravenous administration of photosensitive agents coupled with specific nonthermal laser wavelengths to create more selective destruction of the neovascular complex;8 the intraocular injection of vascular endothelial growth factor (VEGF) inhibitors;9 and the intraocular injection of steroids.10 Other therapies, such as submacular surgery and macular translocation surgery, have been studied as potential additions to the treatment options for eyes with more advanced AMD. While these treatments have offered hope to those seeking to preserve their vision or to arrest further progression of the disease, they also translate into significant use of health resources. Thus, it is important to understand the value of these benefits in terms that are meaningful to patients.

## 1.1 Assessing Visual Functioning and Health-Related Quality-of-Life Measures in Patients with AMD

The clinical presentation of patients with AMD, like that of patients with many other eye and systemic diseases, varies widely, even among patients with similar findings on traditional ophthalmic examination. Patients with similar visual acuities or comparable areas of affected macula often report different degrees of difficulties with their ability to perform visual tasks and other related functions.11 This is not surprising given the wide variation in function associated with another common eye disease affecting central vision, such as cataracts.12,13 Thus, assessing the patient's visual acuity and/or the clinical severity of diseases such as AMD may not always demonstrate the overall effect of the disease on the patient's visual abilities and related abilities to function with their eyesight.14 For example, airline pilots may have functional requirements in their occupation that might be compromised even at measured visual acuities of 20/20. In another context, patients may have 20/20 acuity in office testing conditions, but cannot drive due to glare difficulties with oncoming headlights at night. Thus, visual acuity or contrast sensitivity alone may not adequately reflect the degree of functional impairment or difficulty someone experiences.

Patient-reported visual function and quality-of-life (QoL) measures have become useful adjuncts for evaluating the impact of a patient's visual functioning or disease state on that particular individual and the effects of therapeutic interventions on the individual's level of function. In particular, as patients, providers, and their families appreciate the central importance of “patient-centered care,” greater attention will be focused on how individuals fare with their conditions and how best to ameliorate the impact of their conditions on their abilities to function by using measures that extend beyond conventional physician-directed measures.

There are several potential methods for assessing the impact of eye diseases on individual patients. First, individuals can be observed while performing specific tasks that either replicate activities of daily living or are established proxies for such performance. A leading example is the Salisbury Eye Evaluation (SEE) project, in which West and colleagues15 did such testing on several thousand community-dwelling elders in a population-based study. Other studies have performed related analyses on various clinic-based populations. Second, persons can also be asked to complete questionnaires about what they do and their perceptions of doing so, as with numerous studies assessing many questionnaires.

Such questionnaire instruments have been classically defined into either general health-related QoL questionnaires, such as the Medical Outcomes Study 36-Item Short Form Health Survey (SF-36), the Medical Outcomes Study 12-Item Short Form Health Survey (SF-12), the Sickness Impact Profile (SIP), EuroQol, and similar instruments, or into disease- or condition-specific instruments, such as those for specific eye diseases. Within eye diseases, there are two major forms of questionnaires for vision-related functioning or vision-related quality of life: 1) general vision-related instruments either designed or proven to be useful across a variety of eye conditions; or 2) eye disease-specific questionnaires designed and used (to date) only on one specific eye disease. Such questionnaires may include items concerning not just vision, but also patients' emotional reactions, ocular pain, or other domains adapted from general health-related QoL instruments.

Such patient-reported, eye-specific instruments have now been incorporated into every major clinical trial of interventions to improve the disease course and patient outcomes in patients with AMD and other major eye diseases sponsored by the National Institutes of Health (NIH)/National Eye Institute (NEI), resulting in important data that informs our analysis below. At the same time, they appear to be little used by clinicians, who continue to rely on traditional measures, such as visual acuity, in assessing the degree of success of their treatments. Such an appearance is likely to be misleading, however, for physicians continue to assess the impact of their patients' diseases and treatments through questions in their history-taking, even if they do not use a formal instrument to do so. Thus, it is an opportune time to assess the relative contributions, if any, of these varying methods and instruments to the assessment of the impact of AMD and treatments for AMD on patients.

## 1.2 Questions Posed by the Centers for Medicare and Medicaid Services Regarding Measuring Quality of Life for Patients with AMD

The present evaluation of quality of life for patients with AMD was designed to respond to three specific questions posed by the Centers for Medicare and Medicaid Services (CMS):

1. What is the status of current methods of measuring quality of life of individuals with AMD?
  a. What QoL measurement methods have been used in the AMD population and in those with visual disabilities from AMD (e.g., self-reporting, proxy reporting, measuring performance, etc.)?
  b. Have these QoL measuring methods been used across other eye disease populations?
  c. What are the psychometric properties of these methods (e.g., reliability, validity, responsiveness, etc.)?
2. What are other factors that may influence responses using these methods?
3. How do these QoL measurement methods relate to traditional outcome measures (e.g., visual acuity, contrast, etc.)?

In performing this assessment related to AMD and health-related quality of life, we chose to focus on those methods and instruments that have been used in AMD populations. Thus, the instruments considered under Question 1b are a subset of the instruments considered under Question 1a, not vice versa. In other words, while there are many instruments that have been used for eye diseases other than AMD, if they have not also been used for AMD they were not included in this report. Conversely, for those instruments that have been used in patients with AMD, applications to patients with other types of eye disease were also of interest. Accordingly, our search and inclusion strategies (described below) were first focused toward attempting to find and include all articles pertaining to patients with AMD, and then in finding applications of these instruments outside of AMD. In the following section, we describe the general methods of this assessment.