# Quality-of-Life Instruments

Activities of Daily Vision Scale (ADVS)

Daily Living Tasks Dependent on Vision (DLTV)

National Eye Institute (NEI) Visual Functioning Questionnaire - 25 (VFQ-25)

Referral criteria Action on cataracts (VCM1)

Visual Function Index (VF-14)