# Quality Criteria

1. Is the study population defined in a clinically meaningful way?
  - Are ALL of the following clinical features quantified?
    - Code “+” when ALL the following are quantified;
      - age
      - percent AMD/central vision eye diseases
      - AMD type (wet/dry)
      - unilateral/bilateral
      - objective measure(s) of visual function, (e.g. visual acuity)
    - Code “-“ when NOT ALL of the above are quantified
  - Note: any exclusion criteria that potentially interferes with generalizability are to be noted in the “comments” section of the abstraction form.
2. Is the instrument administered with protection from bias?
  - Code “+” when instrument is administered by an individual who IS masked or otherwise WITHOUT a vested interest in outcome (e.g., not the surgeon or staff)
  - Code “0” when uncertain about masking or identity of person
  - Code “-“ when instrument is administered by an individual who is NOT masked or by an individual WITH a vested interest.
3. Is the statistical power or sample size specified as it relates to analysis of interest?
  - Code “+” when power/sample size IS specified.
  - Code “-“ when power/sample size is NOT specified.