# Evidence Tables

Evidence Table 1 Activities of Daily Vision Scale (ADVS)

Evidence Table 2 Daily Living Tasks Dependent on Vision (DLTV)

Evidence Table 3 Quality of Well-Being Scale (QWB)

Evidence Table 4 Vision Quality of Life Core Measure (VCM-1)

Evidence Table 5 Visual Function Index (VF-14)

Evidence Table 6 National Eye Institute Visual Functioning Questionnaire (NEI-VFQ)