# Search Strategy

Database: Ovid MEDLINE(R) <1966 to August Week 2 2005>

Search Strategy:

--------------------------------------------------------------------------------

1. exp retinal diseases/ (includes Macular Degeneration/ and retinal degeneration/ )
2. exp vision disorders/
3. (vis$ adj1 funct$).mp.
4. 1 or 2 or 3
5. “Quality of Life”/
6. 4 and 5
7. sharma s$.au.
8. coleman a$.au.
9. brown m$.au.
10. brown g$.au.
11. aspinall p$.au.
12. owsley c$.au.
13. mangione c$.au.
14. bressler n$.au.
15. steinberg e$.au.
16. or/7-15
17. 16 and 4
18. 16 and 5
19. 17 or 18
20. 6 or 19
21. limit 20 to english language
22. limit 21 to humans
23. limit 22 to abstracts