# Summary

Pulmonary rehabilitation (PR) is a multidisciplinary and comprehensive intervention for patients with chronic respiratory diseases who are symptomatic, and often have decreased daily activities. Candidate patients for PR may have chronic obstructive pulmonary disease (COPD), asthma, bronchiectasis, ventilator dependency or other diseases. Integrated into the individualized patient care, PR is hypothesized to reduce symptoms, optimize functional status, increase participation, and reduce health care costs through stabilizing or reversing systemic manifestations of the disease. However, PR is not hypothesized to reverse deranged pulmonary mechanics.

This technology assessment is based on a systematic review of the scientific literature and focuses on randomized controlled trials (RCT) or meta-analyses thereof. The key questions that it addresses were formulated by the Agency for Healthcare Research and Quality (AHRQ) and the Centers for Medicare and Medicaid Services (CMS). Briefly, the technology assessment summarizes the available evidence on the efficacy and safety of PR interventions, and describes the influence of patient-level or study-level characteristics.

Exercise training is the cornerstone of PR. For operational purposes we defined PR as any intervention that included an exercise-training component of at least 2 weeks' duration and optionally one or more non-exercise components: educational, psychosocial support, breathing exercises, respiratory muscle training, or nutritional interventions. We placed emphasis on trials applicable to the Medicare population.

Overall this technology assessment is based on a re-analysis of 44 RCT included in three published systematic reviews, and 26 additional RCT that had not been assessed by these reviews. There is little evidence on the effects of PR in diseases other than COPD. The two eligible trials in non COPD population yielded results similar to that obtained from the COPD trials.

Overall, exercise-based PR is effective in improving the patients' disease-specific health-related quality of life, as well as their functional and maximal exercise capacity. Especially in the short term, the improvements are significantly larger than the minimal clinically meaningful improvement. Moreover, evidence suggests that exercise-based PR interventions may reduce hospitalizations and primary care consultations. However, these effects are not translated in survival benefits at least among patients with stable COPD. There is also evidence favoring exercise-based PR among patients recovering from or recently recovered from acute exacerbations of COPD. The assessed RCT did not provide evidence on the safety of PR interventions and on which comorbid conditions predispose patients to/or protect patients from adverse events.

Most of the trials were small and many of them have major methodological shortcomings. Analyses of these trials failed to identify statistically significant differences between PR protocols that included only exercise training versus protocols that also included additional, non-exercise-based, components. The same was true when we compared PR protocols that were tailored to address each patient's specific weaknesses versus PR protocols that were common to all patients; and PR protocols focusing on strength training versus protocols focusing on endurance training or combined strength and endurance training. We should caution that absence of statistically significant findings in the aforementioned comparisons does not imply equivalence of the pertinent PR protocols, and should not be interpreted as such.

Based on few small trials with methodological shortcomings, there is insufficient evidence to draw robust conclusions on whether exercise training has an incremental impact when added to non-exercise PR components like education or inspiratory muscle training, or not. We did not find statistically significant differences when we compared exercise training alone with non-exercise components alone., we did not find statistically significant differences when we assessed the incremental impact of non-exercise components when added to exercise training. However, we stress that all the aforementioned results should be viewed with caution because they are based on few studies of the limited sample sizes methodological shortcomings.