# Results

The literature search identified 2200 citations. After initial screening, 158 citations were considered potentially relevant and full text articles were retrieved. Screening reference lists of reviews and meta-analyses yielded 8 additional papers. Overall, we included 3 systematic reviews (that collectively included 44 RCT), and 26 additional RCT that had not been assessed in the 3 systematic reviews. The majority of the RCT that were already included in the systematic reviews have to be re-reviewed to variable extent to clarify important details when needed.

## Key Question 1 Efficacy and safety of exercise-based pulmonary rehabilitation

### Patients with stable COPD

We identified six systematic reviews/meta-analyses addressing the efficacy and/or safety of PR in patients with stable COPD.6;7;20-23 Of these, five articles were rejected for the following reasons: One was completely covered and updated by the Cochrane review.6 Another, devoted very limited space to the assessment of PR interventions because it aimed at a general overview of contemporary COPD management, and was therefore deemed to be less informative.23 The third21 considered randomized and quasi-randomized trials together, and had employed a different definition of eligible exercise-based PR. The fourth meta-analysis20 focused on the presentation of effect sizes in a unit-free scale, assessed RCT quality using questionable quality items and had different definition of eligible exercise-based PR compared to ours. Finally, the fifth focused only on people with mild-moderate COPD (and thus excluded several eligible studies).22

We included one Cochrane review published in 2002 (last non-substantial update in 2004) that assessed the short term effectiveness of exercise-based PR interventions compared to usual community care.7 The authors scrutinized 23 RCT on patients with stable COPD published between 1977 and 2000. We re-analyzed the 19 (out of 23) trials that provided quantitative data and were eligible according to our inclusion criteria in the meta-analyses described below (Tables 2 through 4).

Table 2 Randomized controlled trials of pulmonary rehabilitation versus usual community included in the Cochrane review: Chronic respiratory disease questionnaire (short term)

Study, year | N_r_ | COPD severity | Male % | Intervention | | CRDQ (95% CI), on a seven point scale | | | | | Quality
Study, year | N_r_ | COPD severity | Male % | Exercise; frequency; setting | Other components | N_a_ (%) | Dyspnea | Fatigue | Mastery of breath | Emotional function | Quality
Cambach, 1997^a,b^ | 23 | II | 57 | LLE (End) + ULE, 3/wk for 12wk; community-based | IMT; Edu | 22 (96) | 1.2 (0.4, 2.0) | 1.3 (0.4, 2.1) | 1.3 (0.3, 2.2) | 0.4 (-0.5, 1.3) | B
Griffiths, 2000^a^ | 200 | III | 54 | LLE (End) + ULE, 3/wk for 6 wk; out-patient + home-based | Edu; Psy; Nutr; SmC | 184 (92) | 1.2 (0.9, 1.5) | 1.1 (0.7, 1.5) | 1.1 (0.7, 1.4) | 1.2 (0.8, 1.5) | A
Goldstein, 1994 | 89 | III | 48 | LLE (End) + ULE (End), ≥3/wk for 8 wk; in-patient | BE; Edu; Psy | 79 (89) | 0.7 (0.1, 1.2) | 0.4 (-0.2, 0.9) | 0.8 (0.2, 1.3) | 0.4 (-0.1, 1.0) | B
Troosters, 2000^c^ | 100 | III | 87 | LLE (End + Str), 3/wk for 12 wk and then 2/wk for 12 wk; out-patient | No | 62 (62) | 0.8 (0.2, 1.5) | 0.7 (0.1, 1.4) | 0.9 (0.2, 1.7) | 0.6 (-0.0, 1.3) | C
Guell,1995 | 60 | III | 100 | LLE (End), 5/wk for 12 wk; out-patient | BE; PD | 56 (93) | 1.3 (0.6, 2.0) | 1.1 (0.5, 1.7) | 1.2 (0.5, 1.9) | 1.0 (0.3, 1.7) | B
Wijkstra, 1994 | 45 | III | 86 | LLE + ULE, 7/wk for 12 wk; home-based | IMT; BE; Edu; Psy | 43 (96) | 0.9 (0.1, 1.7) | 0.6 (-0.1, 1.4) | 0.6 (-0.1, 1.3) | 0.5 (-0.1, 1.1) | B
Hernandez, 2000 | 60 | III | 100 | LLE (End), 6/wk for 12wk; home-based | No | 37 (61) | 0.8 (0.02, 1.5) | 0.9 (0.1, 1.7) | 0.7 (-0.3, 1.6) | 0.5 (-0.3, 1.4) | C
Simpson, 1992 | 34 | III | 54 | LLE + ULE (Str), 3/wk for 8wk; out-patient | No | 22 (65) | 1.2 (0.4, 2.0) | 0.8 (-0.1, 1.6) | 0.7 (-0.4, 1.8) | 0.3 (-0.5, 1.1) | C
Busch, 1988^d^ | 20 | IV | 79 | LLE (End) + ULE (Str+End), 5d/wk for 18 wk; home-based | No | 14 (70) | -0.4 (-2.1, 1.3) | ND | ND | ND | B
Overall, random effects meta-analyses | | | | | | 519 | 1.0 (0.8, 1.2) | 0.9 (0.7, 1.1) | 0.9 (0.7, 1.2) | 0.7 (0.4, 1.0)

Participants in all RCT had mean age above 60 years. Quality scoring is based on the Jadad score and the description of allocation concealment.

RCT are sorted by COPD severity (in what would be the GOLD classification equivalent, judged by the average FEV_1_ values in cases and controls), and then by size. Heterogeneity was statistically non-significant for all four metrics (p-value [I^2^, %] for heterogeneity was 0.53 [0%], 0.48 [0%], 0.87 [0%], and 0.17 [33%] for the four CRDQ scores in the order they are mentioned in the table).

BE: breathing exercises; d: day; CRDQ: chronic respiratory disease questionnaire; Edu: education; End: Endurance training; IMT: inspiratory muscle training; LLE: lower limb exercise; N_a_ number analyzed and % of randomized; ND: No data; N_r_ number randomized; PD: postural drainage; Psy: Psychosocial intervention; RCT: randomized controlled trial; SmC: smoking cessation; Str: strength training; ULE: upper limb exercise; wk: week(s)

a Male proportion refers to patients after dropouts in all trials except for Cambach and Griffiths where it refers to people randomized.

b Refers only to COPD patients; asthmatics in this trial were younger than 59 years on average and are excluded from the technology assessment.

c The Cochrane review names this RCT “Gosselink 2000”

d Only the CRDQ-dyspnea score is reported in this trial

Table 3 Randomized controlled trials of pulmonary rehabilitation versus usual community included in the Cochrane review: Maximal exercise capacity outcome (short term)

Study, year | N_r_ | COPD severity | Male % | Intervention | | ICET | | Quality
Study, year | N_r_ | COPD severity | Male % | Exercise; frequency; setting | Other components | N_a_ (%) | in Watts (95% confidence interval) | Quality
Trials we included in the analyses
Goldstein, 1994 | 89 | III | 48 | LLE (End) + ULE (End), ≥3/wk for 8 wk; inpatient | BE; Edu; Psy | 57 (64) | 0.0 (-8.8, 8.8) | B
Troosters, 2000^b^ | 100 | III | 87 | LLE (End + Str), 3/wk for 12 wk and then 2/wk for 12 wk; out-patient | No | 62 (62) | 11.0 (-7.3, 29.3) | C
Guell,1995 | 60 | III | 100 | LLE (End), 5/wk for 12 wk; out-patient | BE; PD | 56 (93) | 6.4 (-14.2, 26.9) | B
Emery, 1998 | 55 | III | 54 | LLE (End) + ULE, daily for 5wk; out-patient | Edu; Psy | 50 (91) | 11.4 (-6.0, 28.8) | B
Engstrom, 1999 | 55 | III | 52 | LLE (End) + ULE (Str), daily for 52 wk; out-patient | IMT; Edu | 50 (91) | 8.6 (-5.1, 22.3) | B
Wijkstra, 1994 | 45 | III | 86 | LLE + ULE, 7/wk for 12 wk; home-based | IMT; BE; Edu; Psy | 43 (96) | 16.0 (-2.2, 34.2) | B
Hernandez, 2000 | 60 | III | 100 | LLE (End), 6/wk for 12wk; home-based | No | 37 (62) | -5.7 (-23.4, 12.0) | C
Strijbos, 1996 | 35 | III | 87 | LLE (End), 2/wk for 12 wk; out-patient | PD; Edu; Psy | 30 (86) | 12.7 (-0.9, 26.3) | B
Simpson, 1992 | 34 | III | 54 | LLE + ULE (Str), 3/wk for 8wk; out-patient | No | 27 (79) | 26.3 (-93.4, 146.0) | C
McGavin, 1977 | 28 | III | 100 | LLE (End), ≥1/d and ≥5/wk, continuous; home-based | No | 24 (86) | 17.0 (-0.5, 34.5) | B
Jones, 1985 | 19 | IV | 50 | LLE (End) + ULE, for 10 wk; home-based | No | 14 (74) | 27.0 (-172.1, 226.1) | B
Lake, 1990 | 14 | IV | 71 | LLE (End) + ULE, 3/wk for 8 wk; out-patient | No | 14 (100) | 8.9 (-5.0, 23.0) | B
Overall random effects meta-analysis | | | | | | 464 | 7.1 (2.5, 11.8)
Trials we excluded from the analysis (see text)
Vallet, 1994^a^ | 20 | II | 75 | LLE (End), for 8 wk; in-patient | BE | 12 (60) | 0.2 (-0.1, 0.5) | C
Busch, 1988 | 20 | IV | 79 | LLE (End) + ULE (Str+End), 5d/wk for 18 wk; home-based | No | 12 (60) | [different natural quantity]^c^ | C

Layout as in Table 2. Among the first 12 trials, heterogeneity was statistically non-significant (p=0.59, I^2^=0%).

ICET: incremental cycle ergometry test; W: watt(s)

The Cochrane meta-analysis included the last two trials in the table; the results were very similar (5 W [95% confidence interval: 1, 10], p for heterogeneity p-value=0.14 and I^2^=30%). Note that the study by Simpson 1992 did not include endurance training.

a Published in French.

b The Cochrane review names this RCT “Gosselink 2000”

c This trial assessed work, not power: 2643.4 J (-1200.0, 6470.7). It was analyzed together with all the other trials in the Cochrane meta-analysis.

Table 4 Randomized controlled trials of pulmonary rehabilitation versus usual community included in the Cochrane review: Functional exercise capacity outcome (short term)

Study, year | N_r_ | COPD severity | Male % | Intervention | | 6 minute walk test | | Quality
Study, year | N_r_ | COPD severity | Male % | Exercise; frequency; setting | Other | N_a_ (%) | in meters (95% confidence interval) | Quality
Cambach, 1997^a^ | 23 | II | 57 | LLE (End) + ULE, 3/wk for 12wk; community-based | IMT; Edu | 19 (83) | 5.0 (-72.2, 82.2) | B
Goldstein, 1994 | 89 | III | 48 | LLE (End) + ULE (End), ≥3/wk for 8 wk; inpatient | BE; Edu; Psy | 77 (87) | 43.0 (-2.0, 88.0) | B
Troosters, 2000^b^ | 100 | III | 87 | LLE (End + Str), 3/wk for 12 wk and then 2/wk for 12 wk; out-patient | No | 62 (62) | 55.0 (-2.0, 112.0) | C
Guell,1995 | 60 | III | 100 | LLE (End), 5/wk for 12 wk; out-patient | BE; PD | 56 (93) | 83.0 (47.9, 118.1) | B
Engstrom, 1999 | 55 | III | 52 | LLE (End) + ULE (Str), daily for 52 wk; out-patient | IMT; Edu | 50 (91) | 40.0 (-13.5, 93.5) | B
Wijkstra, 1994 | 45 | III | 86 | LLE + ULE, 7/wk for 12 wk; home-based | IMT; BE; Edu; Psy | 43 (96) | 37.0 (-41.3, 115.3) | B
Ringbaek, 2000 | 55 | III | 18 | LLE (End + Str) + ULE (Str), 2/wk for 8/wk; out-patient | No | 36 (65) | 29.0 (-24.4, 82.4) | B
Simpson, 1992 | 34 | III | 54 | LLE + ULE (Str), 3/wk for 8wk; out-patient | No | 28 (82) | 29.0 (-53.5, 111.5) | C
Booker, 1984 | c94 | IV | ND | LLE (End), 1-2/day for 9wk; home-based | BE; PD; Edu; Psy | 69 (73^c^) | 16.0 (-25.3, 57.3) | B
Bendstrup, 1997^d^ | 47 | IV | 56 | LLE (End + Str) + ULE (Str), 3/wk for 12wk; out-patient | Edu; OT; SmC | 32 (68) | 58.2 (22.2, 94.2) | B
Lake, 1990 | 14 | IV | 71 | LLE (End) + ULE, 3/wk for 8 wk; out-patient | No | 14 (100) | 143.6 (74.3, 212.9) | B
Overall, random effects meta-analysis | | | | | | 486 | 50.4 (30.6, 70.2)

Layout as in Table 2. Heterogeneity was statistically non-significant, but only marginally so (p-value=0.11 and I^2^=37%).

ND: Not described; OT: occupational therapy

a Refers only to COPD patients; asthmatics in this trial were younger than 59 y on average and are excluded from the technology assessment.

b The Cochrane review names this RCT “Gosselink 2000”

c This is a three-arm trial. Unclear how many were actually randomized in the two arms, and 94 is an estimate for the 2 arms which have been used here. The percentage of analyzed people (73%) refers to all three arms of this trial.

d Bendstrup 1997 is not included in the meta-analyses in the Cochrane review for unclear reasons (Bendstrup 1997 was among the eligible RCT in the Cochrane review). Inclusion or exclusion of this RCT makes no difference in the final estimates. However, without Bendstup 1997 heterogeneity becomes statistically significant (0.08).

Overall, the included trials were small, as they randomized a median of 50 participants in the compared arms. Reporting of methodological quality items in most trials was moderate to poor. The Cochrane review used the Jadad scale to score the methodological quality of the individual RCT (see appendix C for details on the Jadad scale). The maximum score in the Jadad scale is 5. However, trials on PR interventions cannot be double blinded, and thus the maximum possible Jadad score for PR trials is 4 (double blinding is an item in this quality scale – Appendix C). No trials scored 4 (out of 4) and only six trials scored 3 (out of 4) on the Jadad scale. Exercise training of ambulatory muscles was included in all analyzed trials, and seven trials included training of the upper limbs. The trials varied in the duration, frequency and intensity of training. Overall, endurance training was evaluated in 18 RCT, with additional strength training in four trials.

The included RCT were deemed to have good applicability. The majority of the participants were males (median 71%). The average age ranged from 60 to 73 years, and baseline average FEV_1_ values ranged from 26% to 60% of predicted. Five trials enrolled participants with severe COPD and 13 trials with moderate and/or severe COPD.

#### Dyspnea and disease-specific QoL (CRDQ scores)

Nine trials (277 patients in experimental arm and 242 in the usual community care arm) used the CRDQ instrument.24-31 All assessed the effects on the CRDQ-dyspnea score, and eight assessed all four CRDQ domains (Table 2). There was a clinically meaningful improvement favoring the PR arm in the CRDQ dyspnea, fatigue and mastery of breath domains (i.e., difference at of least 0.5 units in a 7 point scale). The corresponding weighted mean differences in the average change from baseline were 1.0 (95% confidence interval: 0.8, 1.2), 0.9 (95% confidence interval: 0.7, 1.1) and 0.9 (95% confidence interval: 0.7-1.2). The weighted mean difference of the emotional function domain was 0.7 (95% confidence interval: 0.4, 1.0), and the confidence interval could not exclude the minimal clinically significant difference of 0.5 units. There was no statistically significant heterogeneity among the RCT included in the meta-analyses, nor statistically significant differences across subgroups.

#### Maximal exercise capacity

The incremental cycle ergometer test was used to assess the summary effects of PR on the maximal exercise capacity based on 14 trials (255 treated and 233 controls, Table 3).24;26;28-40 We excluded from the summary estimate two trials, one that measured total work in Joules instead of power (Watts)24 and one very small French trial that reported a highly unlikely precise estimate.40 Among the 12 remaining RCT a statistically significant increase in the maximum achieved workload was observed in favor of the PR arm: 7 W (95% confidence interval: 3, 12). It is difficult to interpret the clinical importance of this finding because the minimal clinically meaningful improvement in this test has not been described. There was no statistically significant heterogeneity for this summary estimate and no statistically significant differences across subgroups. The Cochrane review had included the aforementioned trials that were excluded from our analyses; even so the inferences were very similar (weighted mean difference = 5 W [95% confidence interval: 1, 10]).

#### Functional exercise capacity (6MWT)

The Cochrane review included ten RCT (235 treated patients and 219 controls) included in meta-analyses for the 6MWT (Table 4).25;26;29-31;33;34;36;41;42 We included an additional relevant RCT by Bendstrup43 in our re-analysis, which was omitted from the Cochrane review for non-obvious reasons. The WMD in the 6MWT was 52 meters (95% confidence interval: 37, 67), with marginally non-significant heterogeneity. Excluding Bendstrup et al. makes heterogeneity statistically significant (p=0.08) but its extent is more or less the same (I^2^=42%) and the summary results are essentially unchanged. The improvement is not greater than the minimal clinically significant difference in the 6MWT. Hence the clinical significance of this finding is unclear. There were no statistically significant differences across subgroups.

#### Safety

None of the RCT included in the Cochrane review addressed directly any complications secondary to the PR intervention.

#### Mortality and admission rates

Data on mortality were available on seven RCT (Table 5), after follow-up periods ranging from 3 months to 2 years.27;30;33;34;38;43;44 There was no overall effect of exercise-based PR on mortality (odds ratio 1.03, 95% confidence interval: 0.54, 1.89), and there was no statistically significant heterogeneity. In one trial the survival status at 18 months was unclear for some of the dropouts.30 Inferences based on the summary estimate remained similar when all these dropouts were counted as deaths.

Table 5 Randomized controlled trials of pulmonary rehabilitation versus usual community included in the Cochrane review: Mortality

Study, year | N_r_ | COPD severity | Male % | Intervention | | Deaths/Total | | Odds ratio (95% confidence interval) | Quality
Study, year | N_r_ | COPD severity | Male % | Exercise; frequency; setting; follow-up | Other | Intervention | Usual community care | Odds ratio (95% confidence interval) | Quality
Griffiths, 2000^a^ | 200 | III | 54 | LLE (End) + ULE, 3/wk for 6 wk; out-patient + home-based; 12 months | Edu; Psy; Nutr; SmC | 6/99 | 12/101 | 0.48 (0.17, 1.33) | A
Troosters, 2000^a^ | 100 | III | 87 | LLE (End + Str), 3/wk for 12 wk and then 2/wk for 12 wk; out-patient; 18 months | No | 9/37 | 7/33 | 1.19 (0.39, 3.67) | C
Guell,1995 | 60 | III | 100 | LLE (End), 5/wk for 12 wk; out-patient; 24 months | BE; PD | 5/30 | 3/30 | 1.80 (0.39, 8.32) | B
Engstrom, 1999 | 55 | III | 52 | LLE (End) + ULE (Str), daily for 52 wk; out-patient; 12 months | IMT; Edu | 2/26 | 1/24 | 1.92 (0.16, 22.61) | B
Wijkstra, 1994 | 45 | III | 86 | LLE + ULE, 7/wk for 12 wk; home-based; 18 months | IMT; BE; Edu; Psy | 2/28 | 1/15 | 1.08 (0.09, 12.95) | B
Strijbos, 1996 | 35 | III | 87 | LLE (End), 2/wk for 12 wk; out-patient; 18 months | PD; Edu; Psy | 2/18 | 0/15 | 4.70 (0.21, 105.79) | B
Bendstrup, 1997^b^ | 47 | IV | 56 | LLE (End + Str) + ULE (Str), 3/wk for 12wk; out-patient; 3 months | Edu; OT; SmC | 1/20 | 0/22 | 3.46 (0.13, 89.95) | B
Overall, random effects meta-analysis | | | | | | | | 1.03 (0.54, 1.89)

Layout as in Table 2.

Deaths have been calculated with respect to the number of patients followed-up in the corresponding arms, at the longest available follow-up. No statistically significant heterogeneity (p=0.62, I^2^=0%).

a There were 50 randomized patients per arm. 13 and 17 in the intervention and control arm did not attend training sessions or follow-up, and their survival status is unknown. Even if we consider all dropouts dead, the summary odds ratio would be 0.91 (95% confidence interval: 0.54, 1.56), without any heterogeneity (p=0.62, I^2^=0%)

b The number of randomized patients per arm is unclear, because data are reported after 5 post-randomization exclusions.

Data on acute exacerbations of COPD were systematically recorded in three RCT.27;34;43 Of these, two trials reported statistically significant fewer exacerbations or hospitalizations (number of admissions and length of stay) in the PR arm compared with the control arm.27;34 The third trial reported no significant differences across the compared arms.43 Griffiths27 reported that participants in the intervention arm had on average more frequent consultations compared to those in the control arm.

#### Trials published after the Cochrane systematic review

We identified three additional RCT from four publications that assessed the efficacy and safety of PR45-48 (Table 6), all published after the completion of the Cochrane review. The trials enrolled 40 to 191 stable COPD to exercise based PR. One trial was multicenter and assessed PR in the context of a disease management program.45;46 Two trials blinded outcome assessors.45-47 The methodologic quality was good in one trial and poor in the other two.47;48

Table 6 Randomized controlled trials published after the Cochrane review (patients with COPD)

Study, year | Size and applicability | | | PR description | | Difference in change from baseline effect (95% confidence interval) | | Quality
| N_r_ | COPD severity | Male % | Exercise; setting | Other component | CRDQ (Units) | 6MWT (meters) | Quality
Finerty, 2001 | 55 | II | 67 | LLE (End) + ULE, 5/wk for 6 wk; home-based, out-patient | BE; Edu; Nutr; OT | NA | 12 wks: 51m (20 to 81) 24 wks: 53m (p>0.05) | C^a^
Bourbeau, 2003 | 191 | IV | 55 | LLE (End), 3/wk, continuous; home-based | Edu | NA | No significant changes neither within nor between groups at 4 or 12 months | A
Singh, 2003 | 40 | IV | 80 | LLE (End), for 4 wks; home-based | BE; PD | At end of treatment; - Dyspnea: 0.88 (0.26, 1.50); - Function: 0.75 (0.04, 1.46); - Fatigue: 0.84 (-0.04, 1.72); - Mastery: 0.84 (-0.11, 1.79) | 4 wks: 48m (-9, 104) | C^b^

Trials sorted by COPD severity and then by size. As stated in the methods we focused on the same outcomes assessed by the Cochrane review. See text for description of other outcomes.

6MWT: 6 minute walk test; BE: breathing exercises; CRDQ: chronic respiratory disease questionnaire; Edu: education; ICET: incremental cycle ergometry test; ITT: intention to treat; LLE: lower limb exercise; N: number randomized; Nutr: nutritional intervention; OT: occupational therapy; PD: postural drainage; PR: pulmonary rehabilitation; RCT: randomized controlled trial; ULE: upper limb exercise; wk: week(s); y: year(s).

a High attrition; suboptimal RCT reporting of methodological quality items

b Poor RCT reporting of methodological quality items

Two trials reported significantly greater improvements in favor of the intervention arm in St Georges' Respiratory Questionnaire (SGRQ), but failed to exclude the minimal clinically significant differences in this scale.45-47 The third trial by Singh reported scores of CRDQ and the results agreed with the Cochrane review.

Measurements in the 6MWT across the compared arms did not differ beyond chance neither at 4 nor at 12 months of follow-up in one trial.45;46 The trial by Finnerty47 reported that the improvement in the intervention arm was greater by 51 meters at 12 weeks and 53 meters in the 24 weeks (only the former was significant). The third trial by Singh reported a nonsignificant difference of 48 meters favoring the PR arm.48

Reductions in hospitalizations were assessed in Bourbeau only.45;46 They were significantly reduced in the intervention arm both during the first year (-0.7 per patient per year in the PR arm compared with control) and the second year (-0.44 per patient per year compared with control) of follow-up. Similarly, emergency room visits as well as the length of hospitalization were significantly less for the PR arm. No trials evaluated safety outcomes.

### Patients after acute exacerbation of COPD

#### Systematic review

We identified one systematic review on COPD patients that included 6 RCT (140 were randomized to PR and 90 to control) comparing PR after acute exacerbation with conventional care.10 We excluded an RCT because the duration of exercise training was less than 2 weeks.49 The remaining five eligible RCT (described in 6 papers) had sample sizes between 26 and 70 patients50-55 (Table 7). Participants were enrolled after having been hospitalized for acute COPD exacerbations (in one trial both hospitalized and people treated at home were included53). Participants' average age ranged from 64 to 70 years and their mean FEV_1_ from 32% to 40% of predicted (GOLD categories III to IV). Three fourths of the 70 participants in one RCT54 needed mechanical ventilation. Across all RCT, the majority (65 to 90%) of participants were male. The maximum duration of PR intervention was 6 months.50;51;55 Exercise training consisted of aerobic (endurance) and strength exercises in three52;53;55 and endurance exercises only in the remaining two RCT. Follow-up duration ranged from 5 weeks to 18 months. Reporting of methodological quality items in all six trials ranged from poor to moderate.

Table 7 Randomized controlled trials of pulmonary rehabilitation versus conventional care in patients after acute exacerbations of COPD: Trials included in the Puhan et al. systematic review

Study or summary | N_a_ | Follow-up | Outcome | Findings | Comment
Dyspnea instruments other than CRDQ
Behnke, 2003 | 26 | 18 months | TDI | Between arm difference:; - 6.9 (3.9, 9.9) at end of treatment; - 8.6 (6.3, 10.9) at 18 months | Exceeds minimal clinically significant difference
Nava, 1997 | 70 | 6 weeks | VAS | Between arm difference:; - 17 mm (p<0.01) favoring PR | Unclear clinical significance
Quality of life
2 trials (Behnke and Man) | 60 | 12 weeks; 18 months | a,bCRDQ dyspnea | Between arm difference:; - 1.67 (0.36, 1.98), pHet=0.01, I^2^=85% | Very heterogeneous estimate.
2 trials (Behnke and Man) | 60 | 12 weeks; 18 months | bCRDQ-fatigue | WMD between arms:; - 1.37 (1.13, 1.61), pHet=0.26, I^2^=23% | Exceeds minimal clinically significant difference
2 trials (Behnke and Man) | 60 | 12 weeks; 18 months | bCRDQ-mastery | WMD between arms:; - 1.88 (1.67, 2.09), pHet=0.41, I^2^=0% | Exceeds minimal clinically significant difference
2 trials (Behnke and Man) | 60 | 12 weeks; 18 months | bCRDQ-function | WMD between arms:; - 1.36 (0.94, 1.77), pHet=0.29, I^2^=12% | Exceeds minimal clinically significant difference
2 trials (Murphy and Man) | 60 | 12 weeks; 18 months | cSGRQ-total | WMD between arms:; - -11.1 (-17.1, -5.2), pHet=0.53, I^2^=0% | Exceeds minimal clinically significant difference
Functional exercise capacity
(Behnke, Nava, Troosters) | 139 | 5 weeks to 6 months | a6MWT | Between arm difference:; - 114 m (28, 199), pHet<0.01, I^2^=90% | Very heterogeneous estimate, unclear clinical significance
2 trials (Murphy and Man) | 52 | NA | SWT | WMD between arms:; - 81m (48, 115), pHet=0.55, I^2^=0% | Unclear clinical significance
Mortality
2 trials (Murphy and Man) | 52 | NA | Mortality | Relative risk:; - 0.40 (0.18, 0.86), pHet=0.80, I^2^=0% | Including the trial by Nava: relative risk becomes 0.59 (0.34, 1.05), pHet = 0.54, I^2^=0%
Hospital admissions
3 trials (Behnke, Murphy and Man) | 93 | NA | Hospital admissions | Relative risk:; - 0.26 (0.12, 0.54), pHet=0.71, I^2^=0%

CRDQ: Chronic respiratory disease questionnaire; N_a_: number analyzed; NA: not applicable; pHet: p-value for heterogeneity; SGRQ: St George's respiratory questionnaire; SWT: shuttle walk test; TDI: transitional dyspnea index; VAS: Visual analog scale; WMD: weighted mean difference

In parentheses in the findings column 95% confidence intervals are shown.

a The results were heterogeneous and the Puhan review did not synthesize them.

b The review reports that the results are presented on a seven-point scale for CRDQ scores; In this scale the minimal clinically significance difference is 0.5 units.

c Negative SGRQ scores favor the PR arm. Minimal clinically significant difference in the total score is 4 units. The minimal clinically significant difference for TDI is 1 unit.

##### Effects on dyspnea

TDI was assessed in two RCT, which reported greater improvements in the PR arm (Table 7). The confidence intervals for the difference in the changes in TDI from baseline excluded the minimal clinically significant difference of 1 point.56 One other trial evaluated participants who were severely ill and admitted to a respiratory intensive care unit (Nava54). It reported a net change of 17mm on a dyspnea visual analog scale (Table 7) favoring of PR. The clinical significance of the PR effects on dyspnea visual analog scale is not known. Two other heterogeneous trials reported greater improvement in CRDQ-dyspnea in the PR arm compared with the control arm (1.67 [95% confidence interval: 0.36, 1.98].50-52

##### Effects on functional exercise capacity

Three trials50;54;55 assessed patients after acute exacerbation of COPD with the 6MWT. The summary between-arm difference was 114 m favoring the pulmonary rehabilitation intervention (95% confidence interval:28, 199), but this estimate was very heterogeneous (Table 7). Another two trials52;53 assessed the differences in the change from baseline in the Shuttle walk test, and found a summary difference of 81m (95% confidence interval: 48, 115) favoring the intervention (Table 7).

##### Effects on disease specific quality of life

Two trials evaluated disease specific QoL using the CRDQ instrument.50-52 Overall, their meta-analysis suggests there is a net improvement in all four CRDQ domains with PR. The confidence intervals for the WMD exclude (exceed) the minimal clinically significant difference in this instrument (Table 7), implying a clinically meaningful change in all domains, except for the dyspnea domain. One trial reported that the difference in the mean changes of the total SGRQ score was both clinically and statistically significant53 in favor of the PR arm.

##### All cause mortality and hospitalizations

PR appeared to have a protective effect on mortality, with a summary relative risk of 0.40 (95% confidence interval: 0.18, 0.86) with no statistically significant heterogeneity among two trials52;53 (Table 7). This estimate became non-significant when the trial reported by Nava was added in the calculations.54 The latter was conducted among severely ill, high-risk patients with 20% mortality in each arm. The follow-up periods of the synthesized trials ranged from 6 weeks to 18 months.

The relative risk for unplanned hospital admissions was 0.26 (95% confidence interval: 0.12, 0.54) in favor of PR in 3 trials50-53 with no statistically significant heterogeneity.

##### Safety

Two trials (Man and Behnke50-52) specifically stated that any adverse events would be recorded. No adverse events of PR were observed.

#### Subsequent randomized controlled trials

We did not identify any new eligible RCT.

### Patients with non-COPD lung disorders

#### Stable patients

There was only one eligible RCT on participants with non-COPD respiratory disorders especially applicable to the Medicare population.

##### Asthma

We identified a systematic review assessing the effectiveness and safety of exercise training in asthma57 that included trials on participants younger than 40 years old. We excluded it because of the age criterion. We did not identify any new eligible RCT.

##### Bronchiectasis

We excluded one systematic review on physical training for bronchiectasis58 that included RCT published only as abstracts. One moderate quality (grade B) RCT by Newall et al.59 compared physical training versus usual care among patients with bronchiectasis. This was a three arm single-center trial that compared endurance exercise training at 80% of peak HR and IMT training (comprehensive PR, n=11), endurance training and sham IMT training (n=12), and usual care (n=9) as a control. The intervention was administered at home/outpatient based PR administered thrice weekly for 8 weeks. Patients were followed up for 3 months.

The comprehensive PR arm had statistically significantly better improvement in the total SGRQ score compared with the control arm both at the end of the intervention (-7.7 [95% confidence interval: -16.6 to 1.1]) and at the end of the follow-up (-10.0 [95% confidence interval: -21.3 to 1.3]).

For maximal exercise capacity (assessed by the ISWT), the differences in the average change from baseline were 113 meters (95% confidence interval: 46, 181) between the first arm and the control at the end of training, but no data were available at end of follow-up.

Functional exercise capacity assessed with a treadmill endurance test improved more in the comprehensive PR arm (720 meters [95% confidence interval: 280, 1160]; digitized figure data) at the end of training.

Three patients experienced acute disease exacerbations by the end of follow-up in the comprehensive PR. The authors reported no safety data.

#### Patients weaning from mechanical ventilation

We identified no published systematic review for the effects of PR among patients weaning from mechanical ventilation. A single RCT by Porta et al.60 examined the effects of early arm exercise training on the maximal and functional exercise capacity of the arms. The trial was conducted in three respiratory intensive care units in Italy, among 66 critically ill patients who had successfully weaned from mechanical ventilation (MV) between 48 and 96 hours before trial enrollment. Forty-six (70%) of the patients had COPD; the remaining had restrictive chest wall disease (n=10), “cardiosurgical” sequelae (n=6), septic sequelae (n=2), thoracic trauma (n=1), and abdominal surgery sequel (n=1). The majority (83%) had tracheostomy and almost half (n=31) were on long term O_2_ therapy.

Both groups received the standard general physiotherapy treatment with 15 sessions of 20 minutes of additional upper limb exercise in the intervention arm. The exact duration of the program and the length of the follow-up were unclear. Upper limb training increased the maximal exercise capacity of the patients in the arm ergometer (difference in the mean change from baseline between arms 5 W [95% confidence interval: 2, 8] favoring PR); as well as their endurance time at the constant work rate test (difference in the mean change from baseline 4.1 minutes [95% confidence interval: 0.7, 7.6], favoring PR). The clinical significance of these findings is unclear. The patients' perception of dyspnea in the 10-point modified Borg scale immediately after the tests did not seem to be affected by the intervention.

Table 8 summarizes all the findings of the previous analyses.

Table 8 Summary of the efficacy and safety of pulmonary rehabilitation versus conventional care in different patient populations

Studies (Patients); Quality Effect size (95% confidence interval)
Dyspnea and disease-specific QoL | | Maximal exercise capacity | Functional exercise capacity | Mortality
Patients with stable COPD – Cochrane Review
Cochrane review 9 (514) a; A\|B\|C=1\|5\|3^a^ | | Cochrane review 12 (464); A\|B\|C=0\|9\|3 | Cochrane review 11 (486); A\|B\|C=0\|9\|2 | Cochrane review 7 (542); A\|B\|C=0\|9\|2
CRDQ | | ICET: 7.1W (2.5, 11.8)^b^ | 6MWT: 144m (74, 213) | OR = 1.03 (0.54, 1.89)
- dyspnea: | 1.0 (0.8, 1.2) | ICET: 7.1W (2.5, 11.8)^b^ | 6MWT: 144m (74, 213) | OR = 1.03 (0.54, 1.89)
- fatigue: | 0.9 (0.7, 1.1) | ICET: 7.1W (2.5, 11.8)^b^ | 6MWT: 144m (74, 213) | OR = 1.03 (0.54, 1.89)
- mastery: | 0.9 (0.7, 1.2) | ICET: 7.1W (2.5, 11.8)^b^ | 6MWT: 144m (74, 213) | OR = 1.03 (0.54, 1.89)
- emotion: | 0.7 (0.4, 1.0) | ICET: 7.1W (2.5, 11.8)^b^ | 6MWT: 144m (74, 213) | OR = 1.03 (0.54, 1.89)
Patients with stable COPD – RCT published after the Cochrane Review
Subsequent RCT 1 (40); A\|B\|C=\|0\|0\|1 | | ND | Subsequent RCT 2 (246); A\|B\|C=\|1\|0\|1 | ND
| | ND | | ND
CRDQ | | ND | - 1 RCT with 55 patients:; 6MWT: 51m (20, 81)^c^; - 1 RCT with 191 patients:; 6MWT: NS differences | ND
- dyspnea: | 0.9 (0.3, 1.5) | ND | - 1 RCT with 55 patients:; 6MWT: 51m (20, 81)^c^; - 1 RCT with 191 patients:; 6MWT: NS differences | ND
- fatigue: | 0.8 (-0.0, 1.7) | ND | - 1 RCT with 55 patients:; 6MWT: 51m (20, 81)^c^; - 1 RCT with 191 patients:; 6MWT: NS differences | ND
- mastery: | 0.8 (-0.1, 1.8) | ND | - 1 RCT with 55 patients:; 6MWT: 51m (20, 81)^c^; - 1 RCT with 191 patients:; 6MWT: NS differences | ND
- emotion: | 0.8 (0.0, 1.5) | ND | - 1 RCT with 55 patients:; 6MWT: 51m (20, 81)^c^; - 1 RCT with 191 patients:; 6MWT: NS differences | ND
Patients after acute exacerbations of COPD
2 (60); A\|B\|C=0\|1\|1 | | ND | 5 (191); A\|B\|C=0\|1\|4 | 3 (122); A\|B\|C=0\|1\|2
| | ND
CRDQ | | ND | - 3 RCT with 139 patients:; 6MWT: 114m (28, 199); - 2 RCT with 52 patients:; SWT: | - 2 RCT with 52 patients (excluding Nava et al.):; OR = 0.40 (0.18, 0.86); - 3 RCT with 122 patients (including Nava et al.):; OR = 0.59 (0.34, 1.05)
- dyspnea: | 1.7 (0.4, 2.0) | ND | - 3 RCT with 139 patients:; 6MWT: 114m (28, 199); - 2 RCT with 52 patients:; SWT: | - 2 RCT with 52 patients (excluding Nava et al.):; OR = 0.40 (0.18, 0.86); - 3 RCT with 122 patients (including Nava et al.):; OR = 0.59 (0.34, 1.05)
- fatigue: | 1.4 (1.1, 1.6) | ND | - 3 RCT with 139 patients:; 6MWT: 114m (28, 199); - 2 RCT with 52 patients:; SWT: | - 2 RCT with 52 patients (excluding Nava et al.):; OR = 0.40 (0.18, 0.86); - 3 RCT with 122 patients (including Nava et al.):; OR = 0.59 (0.34, 1.05)
- mastery: | 1.9 (1.7, 2.1) | ND | - 3 RCT with 139 patients:; 6MWT: 114m (28, 199); - 2 RCT with 52 patients:; SWT: | - 2 RCT with 52 patients (excluding Nava et al.):; OR = 0.40 (0.18, 0.86); - 3 RCT with 122 patients (including Nava et al.):; OR = 0.59 (0.34, 1.05)
- emotion: | 1.4 (0.9, 1.8) | ND | - 3 RCT with 139 patients:; 6MWT: 114m (28, 199); - 2 RCT with 52 patients:; SWT: | - 2 RCT with 52 patients (excluding Nava et al.):; OR = 0.40 (0.18, 0.86); - 3 RCT with 122 patients (including Nava et al.):; OR = 0.59 (0.34, 1.05)
SGRQ | | ND | - 3 RCT with 139 patients:; 6MWT: 114m (28, 199); - 2 RCT with 52 patients:; SWT: | - 2 RCT with 52 patients (excluding Nava et al.):; OR = 0.40 (0.18, 0.86); - 3 RCT with 122 patients (including Nava et al.):; OR = 0.59 (0.34, 1.05)
- total: | -11 (-17, -5) | ND | - 3 RCT with 139 patients:; 6MWT: 114m (28, 199); - 2 RCT with 52 patients:; SWT: | - 2 RCT with 52 patients (excluding Nava et al.):; OR = 0.40 (0.18, 0.86); - 3 RCT with 122 patients (including Nava et al.):; OR = 0.59 (0.34, 1.05)
Patients with non-COPD lung disorders - Bronchiectasis
1 (20); A\|B\|C=0\|1\|0 | | 1 (20); A\|B\|C=0\|1\|0 | 1 (20); A\|B\|C=0\|1\|0 | ND
| | | | ND
SGRQ:; - total score: Significantly favoring the PR arm | | ISWT: 113m (46, 181) | Treadmill endurance test: 720m (280, 1160) | ND
Patients with non-COPD lung disorders – Weaning from ventilator dependency
ND | | 1 (66); A\|B\|C=0\|1\|0 Arm ergometry: 5W (2, 8) | 1 (66); A\|B\|C=0\|1\|0 Endurance time in constant work rate test: 4.1min (0.7, 7.6) | ND

a The fatigue, mastery and emotion outcomes were based on 8 studies with 505 patients (a study of 14 patients and B quality did not provide these outcomes) - see Table 2

b Some of the primary studies reported kp*m instead of Watts; they have been translated into Watts for these analyses. Two more trials have been excluded from the summary estimates for reasons reported in the text.

c At 12 weeks; similar effects but non-significant at 24 weeks (effect was 53m)

6MWT: 6 minute walk test; COPD: chronic obstructive pulmonary disease; CRDQ: chronic respiratory disease questionnaire; ICET: incremental cycle ergometry; ISWT: incremental shuttle walk test; m: meters; min: minutes; NS: not statistically significant; PR: pulmonary rehabilitation; QoL: quality of life; RCT: randomized controlled trial; SWT: shuttle walk test; W: watt(s)

None of these RCT directly assessed the safety of pulmonary rehabilitation interventions. Effect sizes are differences in the change from baseline for single RCT or weighted mean differences thereof for meta-analyses.

### Subquestion 1.1 Long term effects of pulmonary rehabilitation

The long term safety of PR has been addressed in the previous sections. We identified a systematic review that assessed the long term outcomes of PR,21 which was not preferred over the Cochrane review, as already mentioned in the pertinent section. We identified six trials of poor to good quality that potentially assessed the long term efficacy of PR versus usual community care; they were described in 8 papers.27;30;34;38;39;41;44;61 One did not present any long term outcomes and was excluded from this analysis.41 Another44;61 used follow-up interventions in the experimental arm and is described in a separate section. The remaining four assessed long term efficacy outcomes at 12 to 24 months of follow-up. All trials had high attrition rates, but two of them27;34 analyzed all patients using each participant's latest non-missing measurements. Overall, the effects of the intervention dissipated over time, compared with assessments immediately after the intervention (Table 9). Strijbos38;39 found no statistically significant differences in the Borg scale for exertional dyspnea. Three trials assessed the CRDQ domains or total score and found statistically significant differences that persisted in the long term (Table 8). Summary CRDQ estimates among the two trials that reported them per domain were 0.5 (95% confidence interval: -0.2, 1.2), 0.7 (95% confidence interval: -0.1, 1.4), 0.7 (95% confidence interval: 0.2, 1.1), and 0.5 (95% confidence interval: 0.1, 0.9) for the dyspnea, fatigue, emotional function and mastery of breath domains, respectively. Thus, the clinical significance of these findings is unclear. Functional exercise capacity in the 6MWT was 93 meters (95% confidence interval: 63, 124) in two trials,30;34 implying a clinically significant effect among patients who were successfully assessed in the long term. No improvements were documented for the 4MWT and the shuttle walk test in the other two trials. Finally, maximal exercise capacity was not significantly different across arms in the long term in the two trials that assessed incremental cycle ergometry (summary estimates not available).

Table 9 Randomized controlled trials of pulmonary rehabilitation versus usual community care: Comparison of short term and long term efficacy outcomes (at 1 year or later)

Study, year | Short term efficacy | | Long term efficacy | | Quality
Study, year | Follow-up, N_a_ | Findings | Follow- up, N_a_ | Findings | Quality
Griffiths, 2000 | 6 wk,184 | - CRDQ; dyspnea: 1.2 (0.9, 1.5); fatigue: 1.1 (0.7, 1.5); emotion: 1.2 (0.8, 1.5); mastery: 1.1 (0.7, 1.4); - SGRQ, total: -4 (-8, -0); - Functional exercise capacity, SWT: 73m (44, 102) | 12 mo, 184 | - CRDQ; dyspnea: 0.2 (0.1, 0.4); fatigue: 0.3 (-0.1, 0.6); emotion: 0.5 (0.2, 0.8); mastery: 0.4 (-0.0, 0.8); - SGRQ, total: -4.7 (-8.5, -0.9); - Functional exercise capacity, SWT: 16m (-10, 32) | A
Strijbos, 1996 | 12 wk, 30 | - Exertional dyspnea, Borg scale: -0.1 (-3.3, 3.5); - Functional exercise capacity 4MWT: 31m (-9, 71); - Maximal exercise capacity, ICET: 13W (-1, 26) | 18 mo, 27 | - Exertional dyspnea, Borg scale: 0.2 (-3.3, 3.7); - Functional exercise capacity, 4MWT: 36m (-9, 81); - Maximal exercise capacity, ICET: 7W (-9, 23) | B
Guell, 1995^a^ | 18 wk, 56 | - CRDQ; dyspnea: 1.3 (0.6, 2.0); fatigue: 1.1 (0.5, 1.7); emotion: 1.0 (0.3, 1.7); mastery: 1.2 (0.5, 1.9); - Functional exercise capacity, 6MWT: 83m (48, 118); - Maximal exercise capacity, ICET: 39kp*m (-87, 165) | 24 mo, 56 | - CRDQ; dyspnea: 0.9 (0.4, 1.5); fatigue: 1.1 (0.5, 1.7); emotion: 1.0 (0.3, 1.6); mastery: 0.9 (0.1, 1.8); - Functional exercise capacity, 6MWT: 95m (58, 133); - Maximal exercise capacity, ICET: <20kp*m (p>0.05) | B
Troosters, 2000 | 24 wk, 62 | - CRDQ; dyspnea: 0.8 (0.2, 1.5); fatigue: 0.7 (0.1, 1.4); emotion: 0.6 (-0.0, 1.3); mastery: 0.9 (0.2, 1.7); - Functional exercise capacity, 6MWT: 55m (-2, 112); - Maximal exercise capacity, ICET: 11W (-7, 29) | 12 mo, 49 | - CRDQ, total: 0.9 (0.4, 1.3); (specific domains not available); - Functional exercise capacity, 6MWT: 90m (41, 149); - Maximal exercise capacity, ICET: 13W (4, 22) | B

Trial characteristics have already been presented in Tables 1 to 3. The trial by Booker 1984 also had a long follow-up (12 months) but no results were available. Differences in the change from baseline in the pertinent trials.

a Last observation carried forward for 13 dropouts in the long term follow-up

### Subquestion 1.2 Relationship between pulmonary rehabilitation-associated harms and comorbid conditions

There was no information on whether comorbid conditions prevalent in the Medicare population affected the risk for PR-associated complications. This is because patients with other comorbid conditions (cardiovascular, orthopedic, metabolic or neurologic diseases) were excluded from PR interventions in the primary trials. In addition reporting of comorbid conditions in the trials was poor.

### Subquestion 1.3 Patient level features that modify the effect of pulmonary rehabilitation

Based on the collection of RCT comparing PR versus conventional care, it is unclear what patient level factors affect significantly the effects of PR interventions, either directly, via modifying the participants' gain from the interventions or indirectly, by influencing compliance with the intervention. As mentioned above, the efficacy of PR was not statistically significantly dependent on average disease severity in the corresponding meta-regressions.

### Subquestion 1.4 Comparison of pulmonary rehabilitation with general versus individually targeted exercise

We did not identify any published systematic review that compared general exercise protocols with targeted exercise specific to each patient's needs. We identified only one good quality eligible RTC comparing generalized with individualized exercise-based PR interventions.62 This RCT randomized 180 COPD patients with severe COPD (GOLD IV, mean FEV_1_<1.0L) in a highly individualized training scheme versus a generalized exercise training program. The mean age was 68 years and approximately two thirds of the participants were male. In the individualized training scheme patients were trained only with specific exercises depending on which of their daily activities their disease had the greatest perceived impact. Exercise was performed twice weekly for 7 weeks in an out-patient, supervised setting.

The main outcome was the objective measure of activity using proper devices. There were no statistically significant differences in the four CRDQ domains between the compared arms (the point estimates for differences in the change from baseline for dyspnea, fatigue, emotion and mastery were 0.3 [95% confidence interval: -0.2, 0.8], 0.3 [95% confidence interval: -0.2, 0.8], -0.0 [95% confidence interval:-0.5, 0.4] and 0.1 [95% confidence interval: -0.4, 0.6], respectively). It is evident that the confidence intervals excluded the minimal clinically meaningful difference only for the CRDQ emotional function domain. Patients in both arms were statistically significantly improved compared to baseline (p<0.0001).

Both groups improved their maximal exercise capacity in the cycle ergometer significantly compared to baseline (p<0.0001), but there was no statistically significant difference in the improvement between the two arms: 3.8m (95% confidence interval: -29.1 to 21.5).

Overall 38 patients experienced acute exacerbations of COPD during the trial (15 versus 23 in the individualized versus generalized training arm, respectively), and 6 patients died (3 versus 3 in the two arms respectively). No data on safety were reported.

### Subquestion 1.5 Comparison of pulmonary rehabilitation in different settings and of supervised versus unsupervised pulmonary rehabilitation

We did not find a systematic review that assessed the efficacy of PR in different settings or compared supervised with unsupervised PR. However, we identified three eligible relevant RCT described in five papers.38;39;63-65

An RCT of poor methodological quality by Puente-Maestu et al.64;65 compared physiotherapist-supervised exercise training with unsupervised self-monitored exercise among 49 male patients with severe COPD. Patients in both arms exercised on the treadmill 4 times per week for 8 weeks. Scores in all 4 CRDQ domains improved significantly in both arms after the end of the interventions (unclear whether the improvement was clinically significant). There was no difference between the two arms in the CRDQ scores after the end of the trial. Functional exercise capacity, as measured by endurance time in the cycle ergometer at 70% of baseline peak O_2_ uptake improved more in the supervised training arm. The difference in the mean improvement in endurance time was 3.8 minutes (95% confidence interval: 0.7, 7.1). No data on safety were reported.

Another RCT by Elliott et al.63 compared hospital-based (outpatient, supervised) versus community-based PR (also supervised). Patients were in their sixties, half of them were male and had from moderate to severe COPD. The RCT was of poor methodological quality and had a peculiar design that compared three arms with a complex succession of hospital-based and community-based PR protocols. Because of extensive dropouts (63%) the long term results were neither analyzed nor presented. For the short term results, the two arms that received hospital-based PR were contrasted with the arm that received community-based PR. Both groups showed significant improvements in the total CRDQ score. However, there was no significant difference in the change from baseline between hospital- and community-based PR for this outcome (6.1 [95% confidence interval: -5 to 17]). The corresponding difference for the 6MWT favored the hospital-based group (70 meters [95% confidence interval: 16 to 123]).

A randomized 3-arm trial of poor methodological quality on 45 COPD patients with severe COPD (GOLD III)38;39 allowed the comparison of hospital- versus home-based PR. There was no statistically significant difference in exertional dyspnea (modified Borg scale) between the two settings both at the end of the intervention and at 18 months of follow-up. If anything, patients in the hospital-based PR arm tended to claim worse ratings (by 0.1 and 0.4 on average by the end of the intervention and the follow-up, respectively). There were no statistically significant differences between the compared settings at any time point, both for functional exercise capacity (as assessed by the 4MWT) and for maximal exercise capacity (as assessed by the incremental cycle ergometry test). Patients in the hospital-based PR arm tended to have greater improvement in these outcomes compared to patients in the home-based PR arm.

### Subquestion 1.6 Efficacy of repeated pulmonary rehabilitation programs

Only one RCT evaluated the repeated programs of PR among subjects with moderate COPD and asthma.66 The trial enrolled 61 subjects and only 50% were available at the follow-up. The subjects in the intervention arm had PR at baseline, one year, and two years while subjects in the control arm had PR at baseline and second year. Dyspnea was assessed by means of the TDI and Borg scales and HRQOL was measured with the SGRQ instrument. Patients in each PR program had a statistically significant improvement from baseline for the aforementioned outcomes. However, there were no significant differences between the compared arms. The same pattern was true for functional exercise capacity, which was assessed by the 6MWT: there were improvements beyond chance for each arm, but no statistically significant differences across arms.

### Subquestion 1.7 Efficacy and safety of long term maintenance interventions for pulmonary rehabilitation effects

We identified four RCT in five publications that evaluated efforts to maintain the effects of PR after the end of the PR interventions (Table 10).61;67-70 The trials employed and assessed different strategies to maintain the effects of PR: enhanced follow-up versus conventional follow-up, enhanced follow-up versus no active follow-up, and short term PR versus long term PR. Two trials enrolled subjects with severe COPD;68;70 one trial enrolled subjects with moderate COPD;61 and the fourth trial enrolled subjects with mild COPD.67;69 Home based PR programs were utilized in three trials.61;68;70 One trial in two publications employed PR on out-patient basis.67;69 A total of 478 subjects were included in these trials. Follow-up ranged from 12 to 24 months. All trials were graded as B or C for their methodological quality.

Table 10 Description of randomized controlled trials that assessed maintenance interventions after pulmonary rehabilitation

Author, year | N _r_ /N _a_ | Follow-up (months) | Interventions | Assessed outcomes | Overall Quality
Ries, 2003 | 161/149 | 12 | After the end of PR; - Weekly phone calls and monthly supervised reinforcement sessions; - Letter suggesting to continue PR and invitation to monthly alumni group meetings | TDI CRDQ 6MWT Health care use Mortality | B
Berry, 2003 Foy, 2001 | 140/140 | 18 | - Walking and upper body strength training for 18 months; - Walking and upper body strength training for 3 months | CRDQ 6MWT Mortality | C
Wijkstra, 1996 | 45/36 | 18 | This was a 3 arm RCT: after PR:; - Two arms received physical therapy for 30 min 2/day for 3 months and thereafter 1/day; - The control arm received no intervention | Borg dyspnea score 6MWT Cycle ergometry | C
Brooks, 2000 | 85/41 | 12 | - Invited to attend monthly 2 hour group sessions led by a physical therapist, and phone calls between sessions; - Conventional follow-up: visited the physical therapist every 3 months | CRDQ SGRQ | C

6MWT: 6 minute walk test; CRDQ: chronic respiratory disease questionnaire; N_a/r_: Number analyzed/randomized; PR: pulmonary rehabilitation; SGRQ: ST George's respiratory questionnaire; TDI: transitional dyspnea index.

#### Dyspnea score

Two trials assessed dyspnea in severe to moderate COPD using the TDI and Borg scores.61;70 Both identified that dyspnea worsened over time in the intervention and control arms but there were no differences for the comparisons between arms.

#### Health related quality of life

Three trials evaluated the changes in the CRDQ.68-70 One trial compared the changes in the four domains of CRDQ,69 and the second trial compared changes in the total CRDQ.70 The third trial by Brooks (reference68) described changes in both total and individual domains of CRDQ among severe COPD. For the comparisons of the individual domains of the CRDQ, the decline was significant with time in three of the four domains: dyspnea, fatigue, and mastery. In addition Brooks reported changes in SGRQ that worsened with time but identified no effects across groups. Foy concluded favorable and statistically significant improvement with PR of longer duration among subjects with mild COPD compared to baseline scores in the CRDQ; but there were no significant changes for the comparison between the groups – long term PR versus short term PR.

Two studies that evaluated changes in total CRDQ scores among participants with severe COPD concurred in their results.68;70 Total quality of life scores were worse at 12 months in the intervention and control arms. Brooks found no significant differences between the groups. Ries reported changes in the total CRDQ among severe COPD that showed significant decline in both groups – maintenance care versus enhanced care (−7 versus −10) as well as statistically and clinically significant differences between the groups.

#### Functional exercise capacity

All four trials evaluated the 6MWT at long term follow-up. There was a significant decline in the distance over time among subjects with severe COPD in both arms of two trials but no significant differences between the arms.68;70 Among moderate COPD subjects, the non-active follow-up group showed significant decreases in the walking distance both at 12 and 18 months and no significant changes occurred in those with an active follow-up either with once weekly or once monthly follow-up.61 However at none of the time points did significant differences occur between the three groups evaluated.

#### Inspiratory capacity

One trial evaluated the long term effects of PR on the inspiratory capacity (at rest) among subjects with moderate COPD.61 There was a statistically significant decline in IC with time in subjects who did not have an active follow-up. However these changes were not significant when compared to those with an active follow-up either once weekly or once monthly follow-up.

## Key Question 2 Assessment of specific components in exercise-based pulmonary rehabilitation interventions

What is the efficacy and safety of specific PR components in exercise-based PR interventions?

As mentioned in the introduction, we have addressed 4 subquestions in this topic.

### Subquestion 2.1 Incremental efficacy and safety of exercise training

Trials pertinent to this subquestion follow the comparison scheme below:

#### Exercise training +non-exercise PR component(s) versus the same non-exercise PR component(s)

We identified three eligible trials on COPD patients, which were described in four papers (Table 11).32;71-73 All were small (maximum 66 patients in the compared arms). Applicability for all three RCT was high. The average age of included patients was greater than 65 years. Patients in all trials had from moderate to severe COPD (GOLD III to IV). The RCT by Wedzicha was well designed and well conducted.71;73 Reporting is suboptimal in the other two trials.32;72 Exercise training focused mainly on endurance training of ambulatory muscles in all RCT. The trial by Wedzicha71;73 stratified patients in groups with moderate (Medical Research Council, MRC, 3 to 4) and severe (MRC 5) dyspnea. Attendance was home-based in Larson and the severe dyspnea stratum of Wedzicha and on out-patient basis in the other. The non-exercise PR components were education,71;73 education and psychological intervention (stress management)32 and IMT training.72

Table 11 Randomized controlled trials assessing the incremental effect of exercise training when added to other non-exercise components

Study, year | N_r_ | COPD severity | Male % | Description of compared arms | | N_a_ (%) | Findings | Quality
Study, year | N_r_ | COPD severity | Male % | Exercise; frequency; setting + Other component | Other component | N_a_ (%) | Findings | Quality
Emery, 1998 | 54 | III | 54 | LLE (End) + ULE; 1/d for 5wk, then 3/wk for 60 to 90 min for 5wk; out-patient + Edu; StMan | Edu; StMan | 48 (89) | At end of intervention:; - Maximal exercise capacity, aICET: 93 J (95% CI: -69, 255) | B
Larson, 1999 | ? | III | 66 | LLE (End); 5d /wk, for 4 months; home-based + IMT | IMT | 27 (?) | At end of intervention; - CRDQ dyspnea: -0.1 (-1, 0.8); - CRDQ fatigue: 0.5 (-0.3, 1.1); - Functional exercise capacity, CET: -2W (-19, 15); - Maximal exercise capacity, ICET: 15W (-4, 34) | C
Wedzicha, 1998 & Bestall, 2003 (stratum with 3-4 in MRC dyspnea score) | 66 | IV | 44 | LLE (End) + ULE; 2/wk for 8 wk; out-patients + Edu After the 8 wks till 12 months, 1/mo and advise to exercise at home between 3 and 5 /wk | Edu | 56 (85) | At end of intervention:; - bISWT: 104m (60, 148); - cCRDQ total 8.9 (2.1, 15.8); - SGRQ total -5.5 (-10.7, 0.02); From baseline to 1 year:; - bISWT: 68m (11, 125); - cCRDQ total ≅6; p=0.11; - SGRQ total NS, p=0.27; Differences dissipated between end of treatment and end of follow-up in both arms | B
Wedzicha, 1998 (stratum with 5 in MRC dyspnea score) | 60 | IV | 44 | LLE (End) + ULE; 2/wk for 8 wk; home-based + Edu | Edu | 54 (90) | At end of intervention:; - bISWT: -4m (-31, 22); - cCRDQ total 0.2 (-4.9, 5.5); - SGRQ total 0.9 (-3.9, 0.8) | B

Trials ordered by COPD severity and then by size.

CET: cycle ergometry test; CRDQ: Chronic respiratory disease questionnaire; Edu: education; End: endurance training; ICET: incremental cycle ergometry test; IMT: inspiratory muscle training; ISWT: incremental shuttle walking test; J: Joule(s); LLE: lower limb exercise; MRC: medical research council; N_a_: number analyzed; N_r_: number randomized; ULE: upper limb exercise; SGRQ: St George's respiratory questionnaire; StMan: stress management; wk: week(s)

a Clinical significance unclear.

b this is a maximal exercise capacity outcome

c only the total score is given; Note that this is not reported in a 7-point scale where 0.5 units is the minimal clinically significant difference

e This is a four-arm parallel trial; male percentage for all arms pooled together

#### Dyspnea and disease-specific quality of life

There was a statistically significant difference between the compared arms in the total CRDQ score after the completion of the intervention in the moderate dyspnea stratum of the Wedzicha RCT. The authors comment that the 95% CI does not exclude the minimal clinically significant difference in the total score (Table 11). They did not find a statistically significant difference between the compared arms in the severe dyspnea stratum. Moreover, the improvement dissipated after a year of follow-up (p=0.11). Larson et al. examined the CRDQ dyspnea and fatigue scores and found no significant differences between the compared arms (Table 11).

SGRQ was assessed only in the Wedzicha trial.71;73 Immediately after the intervention, the total SGRQ score favored the arm receiving exercise training (non-significant: -5.5 [95% confidence interval: -10.7, 0.02]). This was not found in the severe dyspnea stratum and disappeared at 1 year of follow-up (p=0.27).

#### Functional exercise capacity

Larson et al did not find statistically significant differences between exercise training plus IMT and IMT alone in functional exercise capacity (-2 W, [95% confidence interval: −19, 15]). In their moderate dyspnea stratum, Wedzicha71;73 found an improvement beyond chance in the incremental shuttle walk test favoring the arm that received exercise training (104 meters [95% confidence interval: 60, 148]). During follow-up, performance in both arms deteriorated (more evidently for patients who received exercise training). At the end of the follow-up there was still a statistically significant difference, but of much smaller magnitude (68 meters [95% confidence interval: 11, 125]).

#### Maximal exercise capacity

Maximal exercise capacity was measured in terms of incremental cycle ergometry testing in two trials.32;72 Emery found no statistically significant difference in the change from baseline (93J [95% confidence interval: -69, 255]). The same was true for Larson (15W [95% confidence interval: -4, 34]) (Table 11).

#### All cause mortality

In the Wedzicha trial71;73 among people in the moderate dyspnea stratum one patient died in the exercise arm versus three patients in the comparator arm by the end of the follow-up (1 year). In the severe dyspnea stratum 0 versus 1 patients died in the corresponding arms by the end of the 8 week intervention.

#### Safety

The RCT pertinent to the specific question did not evaluate adverse events or complications.

### Subquestion 2.2 Efficacy and safety of exercise training compared with other non-exercise PR components

Pertinent trials fit to the comparison scheme described below:

#### Exercise training versus non-exercise PR component(s)

Five RCT, published between 1985 and 1999 could be used to address this subquestion.35;72;74-76 All were on COPD patients with moderate to severe disease (GOLD III to IV). Participants were mostly males and aged above 65 years on average. PR was on out-patient basis in all trials. Hence, applicability to the US healthcare system is considered high. Exercise training included endurance training of ambulatory muscles in all but one trial (Baudolff used only upper limb exercise74). All RCT were small (maximum was 27 patients in both arms) and overall, reporting of methodological quality items was suboptimal.

### Exercise training versus inspiratory muscle training

IMT was the comparator in three RCT.35;72;76 Only Larson assessed quality of life. They found no differences beyond chance between the compared interventions for the dyspnea and fatigue domains that are reported (point estimates were −0.2 and 0.4 respectively, for the exercise training versus IMT comparison) (Table 12).

Table 12 Randomized controlled trials comparing exercise training with non-exercise components

Study, year | Size and applicability | | | Description of compared arms | | N_a_ (%) | Differences between arms | Quality
| N_r_ | COPD severity | Males (%) | Exercise; frequency; setting | Non-exercise component | N_a_ (%) | Differences between arms | Quality
Larson, 1999 | ? | III | 66 | LLE (End); 5/wk for 4 months; home-based | Education | 26 (?) | At end of intervention; - CRDQ dyspnea: 0.7 (+0.0, 1.4); - CRDQ fatigue: 0.2 (-0.7, 1.1); - Functional exercise capacity, CET: -3W (-23, 17); - Maximal exercise capacity, ICET: 15W (-7, 37) | C
Berry, 1996 | 18 | III^a^ | 64 | LLE (End) + ULE (Str); 3/wk for 12 wk; out-patients | Breathing exercises | 17 (94) | At end of intervention; - Borg dyspnea: mean change from baseline 2.5 vs 2.9, NS; - Functional exercise capacity, 12MWT: Significant difference, ANCOVA p=0.03 | C
Larson, 1999 | ? | III | 66 | LLE (End); 5/wk for 4 months; home-based | IMT | 27 (?) | At end of intervention; - CRDQ dyspnea: -0.2 (-0.7, 1.0); - CRDQ fatigue: 0.4 (-0.5, 1.2); - Functional exercise capacity, CET: -5W (-21, 12); - Maximal exercise capacity, ICET: 15W (-4, 34) | C
Jones, 1985 | 22 | IV | 73 | LLE (End) + ULE; for 10 wk; home-based | IMT | 15 (68) | At end of intervention; - Functional exercise capacity, 12MWT: 36m (-75, 147); - Maximal exercise capacity, ICET: 420 J (-637, 1480) | B
Ries, 1986 | 18 | IV | 75 | LLE^b^ (End); 3/d for 6 wk; home-based | IMT | 12 (66) | At end of intervention; - Functional exercise capacity, 12MWT: -69m (-326, 188); bEndurance time: 4.2min (-3.6, 12.0) | C
Bauldoff, 1996 | 20 | IV | 45 | ULE (Unsupported, End + Str); 5/wk for 8 wk; home-based | Phone-call follow-up | 20 (100) | At end of intervention; - Functional exercise capacity, moving of rings; Intervention group moved more rings compared to baseline (p=0.03) but no significant differences between arms (p=0.95) | C

Listed by comparator and then by COPD severity and size

12MWT: 12 minute walk test; CET: cycle ergometry test; CRDQ: Chronic respiratory disease questionnaire; End: endurance training; ICET: incremental cycle ergometry test; IMT: inspiratory muscle training; ISWT: incremental shuttle walking test; J: Joule(s) LLE: lower limb exercise; MRC: medical research council; N_a_: number analyzed; N_r_: number randomized; NS: not significant; ULE: upper limb exercise; SGRQ: St George's respiratory questionnaire; wk: week(s)

a baseline values not reported; the estimate is based on post intervention FEV_1_ which was 45% and 48% in the 2 arms respectively.

b at a rate sustainable for 5 minutes at baseline test

Larson and Jones35;72 assessed maximal exercise capacity by cycle ergometry at the end of the intervention and found no differences beyond chance (point estimates were difference in power of 12 W, and in work of 422 J in the mean changes from baseline, favoring the exercise training arm) (Table 12).

All three assessed functional exercise capacity at end of treatment using either cycle ergometry (Larson72) or the 12MWT.35;76 No significant differences were found between arms (Table 12).

The trials did not assess any survival or safety outcomes.

### Exercise training versus education

The RCT by Larson72 could provide information for this contrast (it is an RCT with four arms). The exercise training arm had a higher improvement in the CRDQ dyspnea score compared with education (difference in the change from baseline of 0.7). However, this was marginally statistically significant and the magnitude of the difference is of unclear clinical significance. No statistically significant differences were found for the CRDQ fatigue domain (the corresponding point estimate was 0.2), the maximal exercise capacity and the functional exercise capacity.

### Exercise training versus breathing exercises

The RCT by Berry75 compared exercise training of ambulatory muscles with breathing exercises. They did not find any statistically significant differences for the mean changes in the modified Borg dyspnea score (mean improvement was 2.5 versus 2.9 in the two arms, respectively). However, they found a significant difference favoring the exercise training arm for the 12MWT functional exercise capacity outcome (p=0.03). No other outcomes of interest were assessed. One patient in each arm had an acute exacerbation of COPD during the intervention.

### Exercise training versus phone follow-up

Finally the RCT by Baudolff compared upper limb exercise with phone follow-up.74 The comparator intervention was perceived as a means to give the same attention to the control group. The only outcome of interest had to do with the functional capacity of the upper arms and was assessed using a ring-moving test. In this test patients are required to move rings passed through a wire for 6 minutes, without touching the wire with the rings. There was a significant improvement in the number of rings moved by the intervention arm compared to baseline (p=0.03), but no statistically significant differences were found between treatment arms (p=0.95). The clinical significance of this finding is unclear. No safety outcomes were assessed.

### Subquestion 2.3 Incremental efficacy and safety of non-exercise pulmonary rehabilitation components

Pertinent trials follow the comparison scheme described below:

#### Exercise-based PR +non-exercise PR component(s) versus the same exercise-based PR

We excluded a systematic overview that assessed this question because it did dot provide details on quality of the pertinent RCT.8

We identified ten relevant trials on patients with stable COPD,72;75;77-84 and one trial on patients with bronchiectasis.59 All were published between 1989 and 2005.

#### COPD patients

The severity of COPD varied from moderate to severe disease (II to IV in the GOLD classification scheme) (Table 13). In general, participant demographics would be considered analogous to COPD patients in the Medicare patient population. Overall, the trials were very small (minimum 11 and maximum 42 analyzed patients) and overall quality was poor to moderate (usual problems were small sample sizes, suboptimal reporting of methodological quality items and high attrition). Endurance training of ambulatory muscles was included in all exercise-training schemes. The added non-exercise PR component was IMT in nine comparisons, and activity training and lecture series in two comparisons described in a single, three-arm RCT.81 Administration of PR was inpatient in three RCT.78;79;82

Table 13 Incremental efficacy of non-exercise PR components when added to exercise-based PR among COPD patients

Study, year | N_r_ | COPD severity | Male % | Description of components | | N_a_ (%) | Findings (PR + added component vs PR) | Quality
Study, year | N_r_ | COPD severity | Male % | Intervention common in both arms (Exercise; frequency; setting +non-exercise PR components) | Added component | N_a_ (%) | Findings (PR + added component vs PR) | Quality
Dekhuizen, 1991 | 40 | II/III | 75 | LLE (End) + torso for 2h; 5/wk for 10 wk; out-patient + Education, breathing exercises, relaxation | IMT | 40 (100) | - Functional exercise capacity, 12MWT: 69m (-141, 279); - Maximal exercise capacity, ICET: -7W (-14.4, 0.4) | B
Wanke, 1994 | 60 | II/III | 54 | LLE (End); 4/wk for 8wk; in-patient | IMT | 42 (70) | - Maximal exercise capacity, ICET: 9W (-11, 29) | C
Mador, 2005 | 38 | III | ND | LLE (End); for 8wk; in-patient + Education | IMT | 29 (76) | - CRDQ dyspnea: -0.6 (-1.3, +0.0); CRDQ fatigue: -0.7 (-1.4, 0.1); CRDQ emotion: -0.2 (-0.9, 0.6); CRDQ mastery: -0.4 (-1.0, 0.2); - Functional exercise capacity, 6MWT: 4m (-70, 78); Endurance CET at 70% of ICET Wmax: -2.4 min (-12.0 to 7.2); - Maximal exercise capacity, ICET: 0W (-15, 15) | C^a,b^
Larson, 1999 | ? | III | 66 | LLE (End); 5d /wk, for 4 months; home-based | IMT | 27 (?) | - CRDQ dyspnea: -0.3 (-1, 0.4); CRDQ fatigue: 0.2 (-0.6, 0.9); - Functional exercise capacity, CET: 3W (-16, 22); - Maximal exercise capacity, ICET: 0W (-23, 23) | C
McKeon, 1986 | 18 | III | ND | LLE (End); 7/wk for 6 wk; home-based | IMT | 18 (100) | - Functional exercise capacity, 12MWT: NS; Endurance stair climbing: NS | C^a^
Berry, 1996 | 18 | III | 64 | LLE (End) + ULE (Str); 3/wk for 12 wk; out-patient | IMT | 17 (94) | - Borg dyspnea score was not significantly different 2.4 (1.2) vs. 2.5 (1.2); - Functional exersise capacity, 12MWT: no significant differences | C
Chen, 1985 | 13 | III | 54 | LLE (End); 3/wk for 4wk; outpatient | IMT | 13 (100) | - Maximal exercise capacity, ICET: 1 W (-23, 25); - Constant work rate at 66% of Wmax, endurance time: 1 min (-4, 2) | C
Weiner, 1992 | 24 | IV | 42 | LLE + ULE (End + Str) for 30 min; 3/wk for 6mo; outpatient | IMT | 24 (100) | - Functional exercise capacity, 12MWT: 435m (173, 697); CET, endurance at 60% of Wmax: 1.9min (-0.8, 4.6) | C
Goldstein, 1989 | 12 | IV | 84 | LLE + ULE (End); unclear intensity and frequency; in-patient + Education, breathing retraining, relaxation classes | IMT | 11 (92) | - Functional exercise capacity, 6MWT: -64m (-198, 70); Submaximal endurance in CET: -1.1 min (-7.1, 4.9) | C^a^
Norweg, 2005^c^ | 28 | II | 51 | LLE + ULE; 2/wk for 3 wk (supervised) and 2 to 3/wk at home; out-patient + home-based | Activity training | ^e^28 (100) | - CRDQ dyspnea 0.7 (p>0.05); CRDQ fatigue 0.6 (p>0.05); CRDQ mastery -0.1 (p>0.05); CRDQ emotion -0.3 (p>0.05); - Functional exercise capacity, 6MWT: no significant difference | B
Norweg, 2005^c^ | 33 | II | 51 | LLE + ULE; 2/wk for 3 wk (supervised) and 2 to 3/wk at home; out-patient + home-based | Education | ^e^33 (100) | - CRDQ dyspnea -0.3 (p>0.05); CRDQ fatigue 0.1 (p>0.05); CRDQ mastery -0.8 (p<0.05); CRDQ emotion -0.7 (p>0.05); - Functional exercise capacity, 6MWT: no significant difference | B

Trials are ordered by added component (IMT, activity training, education), then by COPD severity and decreasing sample size. Main reason for rating the trials as quality C was poor reporting of methodological quality items. Additional reasons are presented when applicable.

A random effects meta-analysis of the available ICET outcomes for the five trials with IMT as the added non-exercise component yields 6/12MWT: 6/12 minute walk test; CET: cycle ergometry test; CRDQ: Chronic respiratory disease questionnaire; End: endurance training; ICET: incremental cycle ergometry test; IMT: inspiratory muscle training; LLE: lower limb exercise; MRC: medical research council; N_a_: number analyzed; N_r_: number randomized; NS: not significant; ULE: upper limb exercise; wk: week(s)

a Suboptimal analysis

b Cluster randomized, with unclear description of cluster formation and exact cluster size

c This trial has three arms: exercise training alone (n=18), exercise training and activity training (n=10), and exercise training and education (lecture series) (n=15). Optimally analyzed with mixed models accounting for missing information across repeated measurements but with few patients per arm.

Overall, there were no significant differences in the health-related quality of life measures, the functional exercise capacity or the maximal exercise capacity between exercise-based PR without and with the added components. Random effects meta-analyses yielded non-significant differences between the two arms regarding the CRDQ dyspnea, CRDQ fatigue, maximal and functional exercise capacity and endurance time at 60% to 70% of maximum workload (Table 14). We caution that these results should not be interpreted as proof of equivalence of the compared arms, because of the small sample size of the meta-analyzed trials, their methodological shortcomings, and the fact that all these trials were not designed to assess equivalence. There was a worsening in the CRDQ mastery domain when education was added to exercise training in the Norweg81 RCT (by 0.8 units on average, adjusted for age, baseline values, and repeated measurements). This finding has limited if any clinical meaning.

Table 14 Random effects meta-analyses of the incremental efficacy of IMT when added to exercise-based PR among COPD patients

Outcome | Meta-analysed RCT | Number of participants | Weighted mean difference (95% confidence interval) | Heterogeneity p (I^2^ [%])
CRDQ, dyspnea | Mador, 2005 Larson, 1999 | 56 | -0.5 (-0.9, +0.0) | 0.54 (0)
CRDQ, fatigue | Mador, 2005 Larson, 1999 | 56 | -0.3 (-1.1, 0.6) | 0.10 (64)
Functional exercise capacity, 12MWT | Dekhuizen, 1991 Weiner, 1992 | 64 | 243 m (-115, 601) | 0.03 (78)
Maximal exercise capacity, ICET | Dekhuizen, 1991 Wanke, 1994 Mador, 2005 Larson, 1999 Chen, 1985 | 151 | -3.6 W (-9.5, 2.3) | 0.59 (0)
Endurance time, constant work rate between 60 and 70% of maximum workload | Mador, 2005 Weiner, 1992 Goldstein, 1989 | 64 | 1.3 min (-0.6, 3.3) | 0.67 (0)

Trials are ordered as in table 13.

The aforementioned RCT did not consistently report data on mortality, acute exacerbations, or safety and harms.

#### Patients with bronchiectasis

We identified a single RCT by Newall59 that assessed the incremental impact of IMT in patients with bronchiectasis. Participants attended out-patient, lower limb, exercise training. This was a three-arm trial; here we utilize information from two arms only (exercise training with IMT versus exercise training alone). Generalizability to the Medicare population was good. The RCT was of moderate methodological quality (B in an A to C scale).

There was a trend for better scores in the total SGRQ scale favoring the arm with combined exercise and IMT training at 3 months of follow-up. However, this was statistically non-significant (mean difference in the changes from baseline was −12.3 [95% confidence interval: -24.7, 0.1]). There was no statistically significant difference in the maximal exercise capacity, as measured by the incremental shuttle walk test (difference in the mean changes from baseline was approximately 76 m at 3 months of follow-up, but statistically non-significant). Patients in the combined IMT and exercise arm had greater endurance in a constant work rate treadmill test at 85% of peak O_2_ uptake (the corresponding difference was approximately 500 meters).

### Subquestion 2.4 Efficacy and safety of different modes of exercise training

Here we assess different exercise training protocols:

a. Higher versus lower intensity training
b. Endurance versus strength exercise training
c. Interval versus continuous training

We identified a published systematic review by Puhan9 that addressed these three specific questions. Another systematic review by O'shea et al was identified,85 but was not selected as the basis for our assessments. This is because the O'shea systematic review did not organize the available RCT in meaningful contrasts allowing for a quantitative assessment of the key questions. Thus, it did not provide quantitative syntheses for the outcomes of interest. Moreover, the Puhan9 systematic review has identified more RCT.

#### Higher versus lower intensity training

The systematic review identified two trials reported in three papers86-88 that directly compared higher versus lower intensity training and reported eligible outcomes. Both trials were not eligible according to our inclusion criteria; one did not report any outcome of interest,88 and the other was on patients younger than 59 years on average.86;87 We did not identify any other eligible RCT addressing higher versus lower intensity training.

#### Endurance versus strength training

There were eight relevant RCT reports identified by the systematic review.79;89-95 We did not identify any other eligible RCT. We present in different sections the comparison between endurance versus strength training (Tables 15 and 16) and the comparison between endurance and combined endurance and strength training (Tables 17 to 19).

Table 15 Randomized controlled trials comparing endurance versus strength exercise training, included in the Puhan et al. meta-analysis: health related quality of life (CRDQ) outcomes

Study, year | N_r_ | COPD severity | Male % | Exercise; frequency + other components | | CRDQ (95% confidence interval), on a seven point scale | | | | | Quality
Study, year | N_r_ | COPD severity | Male % | Endurance | Strength | N_a_ (%) | Dyspnea | Fatigue | Mastery | Emotional function | Quality
Normandin, 2002 | 54 | II/III | 53 | LLE at 80% of W_max_ for 10-30 min; 3/wk for 10wk + Edu | LLE + ULE, 8-10 repetitions, low intensity; 3/wk for 10 wk + Edu | 40 (74) | -0.3 (-0.9, 0.3) | -0.3 (-0.9, 0.3) | -0.2 (-0.6, 0.2) | -0.4 (-1.0, 0.2) | C
Spruit, 2002 | 48 | III | 80 | LLE 30-75% of W_max_ + ULE for 25 to 60 min; 3/wk for 12 wk | LLE + ULE, 3*8 repetitions at ≥70% of 1 RepMax; 3/wk for 12 wk | 30 (63) | 0.3 (-0.8, 1.3) | 0.0 (-1.0, 1.0) | -0.3, (-1.1, 0.6) | 0.0 (-0.8, 0.8) | C
Ortega, 2002 | 36 | III | 87 | LLE at 60% of W_max_ for 40 min; 3/wk for 12wk + Edu | LLE + ULE, 6-8 repetitions at 70-85% of 1 RepMax; 3/wk for 12 wk + Edu | 33 (92) | 0.0 (-0.6, 0.6) | -0.4 (-1.0, 0.2) | -0.1 (-0.6, 0.4) | -0.7 (-1.2, -0.2) | B
Overall, random effects meta-analysis | | | | | | 103 | -0.1 (-0.5, 0.3) | -0.3 (-0.7, 0.2) | -0.2 (-0.5, 0.2) | -0.4 (-0.7, -0.0)

Trials ordered by COPD severity and then by decreasing sample size.

Heterogeneity was statistically non-significant for all four domains. Heterogeneity p-values were non-significant and I^2^ values were 0% for all 4 outcomes.

CRDQ: Chronic respiratory disease questionnaire; CI: confidence interval; Edu: education; LLE: lower limb exercise; N_a_: number analyzed; ND: No data available; N_r_: number randomized; NS: not significant; PR: pulmonary rehabilitation; Rel: relaxation techniques; RepMax: (1) repetition maximum; ULE: upper limb exercise; wk: week(s); W_max_: maximum workload.

Table 16 Randomized controlled trials comparing endurance versus strength exercise training, included in the Puhan et al. meta-analysis: outcomes other than those presented in Table 15

Study, year | N_r_ | COPD severity | Male % | Exercise training; frequency + other PR | | N_a_ (%) | Dyspnea and exercise capacity | Other | Quality
Study, year | N_r_ | COPD severity | Male % | Endurance | Strength | N_a_ (%) | Dyspnea and exercise capacity | Other | Quality
Wurttemberger, 2001^a^ | ? | II/III | 64 | LLE at 70% of W_max_ for 20 min; 3/wk for 3wk + Psy; Rel | LLE + ULE, 2-4*20-25 repetitions at 40% of 1 RepMax; 3/wk for 3 wk + Psy; Rel | 46 (?) | - Functional exercise capacity, 6MWT:; stratum 1: 17m (-46, 80); stratum 2: 14m (-31, 59) | ND | B
Normandin, 2002 | 54 | II/III | 53 | LLE at 80% of W_max_ for 10-30 min; 3/wk for 10wk + Edu | LLE + ULE, 8-10 repetitions, low intensity; 3/wk for 10 wk + Edu | 40 (74) | - Dyspnea, TDI: -0.3 (-1.7, 1.1); - Functional exercise capacity, CWR: -5.7min (-8.4, 3.0) | - Acute exacerbations 3 vs 4 | C
Ortega, 2002 | 36 | III | 87 | LLE at 60% of W_max_ for 40 min; 3/wk for 12wk + Edu | LLE + ULE, 3*8 repetitions at ≥70% of 1 RepMax; 3/wk for 12 wk + Edu | 33 (92) | - Dyspnea, BDI: no SS differences; - Functional exercise capacity SWT: -70m (-159, 19) CWR: -25.3min (-38, -13); - Maximal exercise capacity, ICET: 6W (-2, 14) | - Acute exacerbations unclear, but <4 in total | B
Spruit, 2002 | 48 | III | 80 | LLE 30-75% of W_max_ + ULE for 25 to 60 min; 3/wk for 12 wk | LLE + ULE, 3*8 repetitions at ≥70% of 1 RepMax; 3/wk for 12 wk | 30 (63) | - Functional exercise capacity, 6MWT: 16m (-32, 64); - Maximal exercise capacity, ICET: -1W (-12, 10) | - Acute exacerbations 5 vs 7 | C

Trials ordered by quality and decreasing sample size.

6MWT: 6 minute walk test; BDI: baseline dyspnea index; BE: breathing exercises; CRDQ: Chronic respiratory disease questionnaire; CWR: constant work rate; Edu: education; LLE: lower limb exercise; m: meter(s); N_a_: number analyzed; ND: No data available; N_r_: number randomized; NS: not significant; PR: pulmonary rehabilitation; Rel: relaxation techniques; RepMax: (1) repetition maximum; SWT: shuttle walk test; ULE: upper limb exercise; W: watt(s); wk: week(s); W_max_: maximum workload.

a Trial published in German; results presented separately for two different patient strata (with and without O_2_ desaturation during exercise). Very consistent estimates with the Spruit et al. trial in the 6MWT.

Table 17 Randomized controlled trials comparing endurance versus combined endurance and strength exercise training, included in the Puhan et al. meta-analysis: health related quality of life (CRDQ) outcomes

Study, year | N_r_ | COPD severity | Male % | Exercise; frequency + other component | | CRDQ (95% confidence interval), on a seven point scale | | | | | Quality
Study, year | N_r_ | COPD severity | Male % | Endurance | Endurance/Strength | N_a_ (%) | Dyspnea | Fatigue | Mastery | Emotional function | Quality
Bernard, 1999 | 45 | III | 78 | LLE at 80% of W_max_ for 30 min; 3/wk for 12wk + BE; Rel | LLE endurance/LLE and ULE strength; 3/wk for 12wk + BE; Rel | 36 (80) | 0.1 (-0.4, 0.6) | 0.2 (-0.3, 0.7) | 0.6 (-0.1, 1.0) | 0.0 (-0.5, 0.5) | B
Ortega, 2002 | 36 | III | 87 | LLE at 60% of W_max_ for 40 min; 3/wk for 12wk + Edu | LLE endurance/LLE and ULE strength; 3/wk for 12 wk + Edu | 31 (86) | 0.1 (-0.3, 0.5) | 0.1 (-0.4, 0.6) | -0.5 (-0.9, 0.1) | -0.5 (-0.9, -0.1) | B
Mador, 2004 | 32 | III | ND | LLE at ≥50% of W_max_ for 35 min; 3/wk for 8 wk + Edu | LLE endurance/LLE and ULE strength; 3/wk for 8 wk + Edu | 24 (75) | 0.2 (-0.3, 0.7) | 0.2 (-0.5, 0.8) | -0.2 (-0.8, 0.5) | 0.0 (-0.3, 0.4) | C
Overall, random effects meta-analysis | | | | | | 93 | 0.3 (-0.0, 0.5) | 0.2 (-0.1, 0.5) | 0.1 (-0.3, 0.5) | -0.2 (-0.5, 0.2)

Trials ordered by quality and decreasing sample size.

Heterogeneity was statistically non-significant for the dyspnea and fatigue domains, and significant (p<0.1) for the mastery and emotional function domains. BE: breathing exercises; CRDQ: Chronic respiratory disease questionnaire; CI: confidence interval; Edu: education; LLE: lower limb exercise; N_a_: number analyzed; N_r_: number randomized; NS: not significant; PR: pulmonary rehabilitation; Rel: relaxation techniques; ULE: upper limb exercise; wk: week(s); W_max_: maximum workload.

Table 18 Randomized controlled trials comparing endurance versus combined endurance and strength exercise training, included in the Puhan et al. meta-analysis: functional and maximal exercise capacity outcomes

Study, year | N_r_ | COPD severity | Male % | Exercise; frequency + other component | | Functional and maximal exercise capacity outcomes (95% confidence interval) | | | Quality
Study, year | N_r_ | COPD severity | Male % | Endurance | Endurance/Strength | Na (%) | 6 minute walk test (m) | Incremental cycle ergometry (W) | Quality
Wurttemberger, 2001^a^ | ? | II/III | 64 | LLE at 70% of W_max_ for 20 min; 3/wk for 3wk + Psy; Rel | LLE endurance/LLE and ULE strength; 3/wk for 3 wk + Psy; Rel | 24 (?) | -5 (-34, 45) | 4 (-7, 16) | B
Wurttemberger, 2001^a^ | ? | II/III | 64 | LLE at 70% of W_max_ for 20 min; 3/wk for 3wk + Psy; Rel | LLE endurance/LLE and ULE strength; 3/wk for 3 wk + Psy; Rel | 22 (?) | 1 (-48, 50) | 3 (-8, 14) | B
Bernard, 1999 | 45 | III | 78 | LLE at 80% of W_max_ for 30 min; 3/wk for 12wk + BE; Rel | LLE endurance/LLE and ULE strength; 3/wk for 12wk + BE; Rel | 36 (80) | -22 (-60, 16) | 1 (-7, 9) | B
Ortega, 2002 | 36 | III | 87 | LLE at 60% of W_max_ for 40 min; 3/wk for 12wk + Edu | LLE endurance/LLE and ULE strength; 3/wk for 12 wk + Edu | 31 (86) | NA | 6 (-5, 17) | B
Sivori, 1998^b^ | ? | III | 89 | LLE at 70% of W_max_; 3/wk for 8wk | LLE endurance/ULE strength; 3/wk for 8wk | 28 (?) | NA | -10 (-22, 3) | C
Mador, 2004 | 32 | III | ND | LLE at ≥50% of W_max_ for 35 min; 3/wk for 8 wk + Edu | LLE endurance/LLE and ULE strength; 3/wk for 8 wk + Edu | 24 (75) | -8 (-31, 15) | -3 (-16, 9) | C
Overall, random effects meta-analysis | | | | | | | -7 (-24, 9) | 1 (-4, 5)

Trials ordered by severity, and then by quality and decreasing sample size. Heterogeneity was statistically non-significant for both outcomes.

BE: breathing exercises; CWR: constant work rate; Edu: education; LLE: lower limb exercise; m: meter(s); N_a_: number analyzed; N_r_: number randomized; NS: not significant; Psy: Psychosocial intervention; Rel: relaxation techniques; ULE: upper limb exercise; W: Watt(s); wk: week(s); W_max_: maximum workload.

The confidence intervals pertain to between-arm differences in the change from baseline.

a Trial published in German; results presented separately for two different patient strata (with and without O_2_ desaturation during exercise). Results are essentially the same excluding this trial.

b Trial published in Spanish; results are essentially the same excluding this trial.

Table 19 Randomized controlled trials comparing endurance versus combined endurance and strength exercise training, included in the Puhan et al. meta-analysis: outcomes other than those reported in Tables 17 and 18

Study, year | Size, applicability | | | Exercise training; frequency + other PR | | N_a_ (%) | Findings | Quality
Study, year | N_r_ | COPD severity | M (%) | Endurance | Endurance/Strength | N_a_ (%) | Findings | Quality
Bernard, 1999 | 45 | III | 78 | LLE at 80% of W_max_ for 30 min; 3/wk for 12wk + BE; Rel | LLE endurance/LLE and ULE strength; 3/wk for 12wk + BE; Rel | 36 (80) | - Acute exacerbations 3 patients, unclear in which arm | B
Ortega, 2002 | 36 | III | 87 | LLE; 3/wk for 8wk | LLE endurance/ULE strength; 3/wk for 12 wk + Edu | 31 (86) | - Constant work rate test (min): 10 (-4, 23) | C
Mador, 2004 | 32 | III | ND | LLE at ≥50% of W_max_ for 35 min; 3/wk for 8 wk + Edu | LLE endurance/LLE and ULE strength; 3/wk for 8 wk + Edu | 24 (75) | - Constant work rate test (min): 0.3 (-7.5, 8.1) | C
Ries, 1988^a^ | 30 | III | ND | LLE at 60% of W_max_ for 40 min; 3/wk for 12wk + Edu | LLE endurance/ULE strength; 3/wk for 12 wk + Edu | 18 (60) | - Functional exercise capacity Arm ergometry endurance time: NS differences; - Safety; 1 patient dropped out due to low back pain, attributed to the intervention | C

Trials ordered by quality and then by decreasing sample size.

BE: breathing exercises; Edu: education; LLE: lower limb exercise; M: males; N_a_: number analyzed; N_r_: number randomized; NS: not significant; Rel: relaxation techniques; ULE: upper limb exercise; wk: week(s); W_max_: maximum workload.

a three arm trial; here we contrast the LLE arm with the proprioceptive neuromuscular facilitation arm which received strength training exercises. The remaining arm received endurance exercises of the upper limb.

There were four RCT that compared endurance versus strength training in COPD patients (disease severity GOLD II to III),90;91;94;95 all published in 2001 and 2002. Patient characteristics are generalizable to the Medicare population of interest. Reporting of methodological quality items these trials was suboptimal, and two90;94 had almost 30% attrition rate. One trial was published in German.95

Dyspnea outcomes were assessed in three90;91;94 (Tables 15 and 16) of the four trials. Normandin (n=40) and Ortega (n=33) did not find a difference between the compared exercise modalities in the TDI/BDI instrument (Table 15). All three RCT assessed the four CRDQ domains (n=103 randomized patients). The changes from baseline in the dyspnea, fatigue and mastery CRDQ domains did not differ beyond chance between the two exercise modalities (Table 15). There was a formally significant difference in favor of strength training for the emotional function domain, but this was only marginally statistically significant and of unclear clinical significance (point estimate -0.4 [95% confidence interval: -0.7, -0.0], Table 15).

Two papers reported data on the 6MWT.94;95 One of them95 was published in German and reported outcomes in separate strata of patients (patients with or without O_2_ desaturation during training). The overall synthesis showed clinically negligible and non-significant differences between the different exercise modalities (15 meters [95% confidence interval: -14, 44]). The summary synthesis excluded the minimal clinically significant difference of 54 meters in the 6MWT. Results were very consistent across these two trials (Table 16). Another two trials90;91 showed significantly greater improvements in favor of strength training for constant work rate test endurance (by approximately by 6 minutes in Normandin and 26 minutes in Ortega). However, individual estimates were very different and their confidence intervals did not overlap. Two trials assessed maximal exercise capacity with the incremental cycle ergometry test.91;94 Their synthesis did not show any formally significant differences between endurance and strength training (4 W [95% confidence interval: −3, 10] favoring endurance exercise training).

There was no difference in the rate of acute COPD exacerbations between the compared arms in the two trials that reported them90;91 (Table 14, OR 0.67 [95% confidence interval: 0.24, 1.86] favoring endurance training). None of these trials assessed any mortality or safety outcomes.

Finally, the systematic review identified six RCT that compared endurance training versus combined endurance and exercise training.79;89;91-93;95 These RCT were published between 1988 and 2004, and two (Ortega,91 Wurtemberger95) were mentioned in the previous paragraphs. Two reports, one by Wurttemberger95 and one from Sivori93 were published in German and Spanish respectively. Participants were predominantly male and mean ages were 63 years old or older. All were on COPD patients with severity II or III in the GOLD classification scheme. All trials included exercise training of ambulatory muscles (Tables 17 to 19), except for Ries,92 where upper limb exercise training was employed. Overall, the methodological quality of these RCT was poor to moderate (grades C to B, respectively).

There were no differences between the compared arms for the four CRDQ domains in three trials (n=93 patients in total).79;89;91 In fact the 95% confidence intervals of the syntheses practically excluded the clinically significant difference of 0.5 units in all four domains (Table 17).

Functional exercise capacity, as conveyed by the 6MWT was assessed in three trials with 106 analyzed participants.79;89;95 The summary estimates' confidence intervals excluded the minimal clinically significant difference in the 6MWT (54 meters, Table 18). Inferences were similar after excluding data from the German report.95

Similarly, there were no statistically significant differences between the compared arms with respect to the maximal exercise capacity in the incremental cycle ergometry test among 165 analyzed COPD patients (1 W [95% confidence interval: -4, 5], Table 17) (references79;89;91;93;95). Inferences were very consistent when the non-English language reports93;95 were excluded. The trial by Ries92 assessed maximal exercise capacity of the upper limbs, and found no differences between the compared exercise modalities (Table 19).

Finally, no statistically significant differences were found in the constant work exercise tests in two trials by Mador79 and Ortega91 (Table 18). The number of patients with acute exacerbations in each arm was not reported in any of the trials (Table 19). Only Ries92 reported that a patient dropped out of the trial because of low back pain that was attributed to exercise training.

#### Continuous versus interval training

The systematic review assessed three trials published between 1999 and 2002 (references96-98) that compared continuous training with interval training in people with COPD. One of them (Kaelin97) has been reported as a meeting abstract. We identified an additional eligible RCT99 published after the systematic review on the same topic. We comment on all four trials in the following paragraphs.

Participants were predominantly males (62% to 100%), had COPD severity III to IV in the GOLD classification scheme and their mean age was in the age range of interest. The trials' methodologic quality was poor to moderate. All were small in terms of sample size (13 to 36 analyzed patients). Exercise training of ambulatory muscles was the main exercise in all trials.

Only one trial98 assessed the four CRDQ domains, and found no differences between the compared arms. Kaelin97 was the only trial that assessed functional exercise capacity, and found a statistically non-significant trend favoring the continuous exercise arm (41 meters, [95% confidence interval: -17, 99], based on only 13 patients). Maximal exercise capacity with incremental cycle ergometry testing was assessed in three trials.96;98;99 None found statistically significant differences (Table 20). A meta-analysis of maximal exercise capacity outcomes was not feasible because of missing data on the uncertainty of the estimates in two of the three trials96;98 (Table 20).

Table 20 Randomized controlled trials of pulmonary rehabilitation interventions comparing continuous versus interval exercise training

Study, year | N_r_ | COPD severity | Male % | Exercise training; frequency + other component | | N_a_ (%) | Differences between exercise training modalities | Quality
Study, year | N_r_ | COPD severity | Male % | Continuous | Interval | N_a_ (%) | Differences between exercise training modalities | Quality
Included in the Puhan et al systematic review
Vogiatzis, 2002 | 45 | III | 62 | LLE up to 70% of W_max_; 2/wk for 12 wk + Edu; BE; Psy; Rel | LLE up to 140% of W_max_ (30 s) and 45% of W_max_ (30 s) + Edu; BE; Psy; Rel | 36 (80) | - CRDQ; dyspnea: 0.5 (NS); fatigue: 0.0 (NS); mastery: 0.0 (NS); emotion: 0.2 (NS); - Maximal exercise capacity, ICET: -1W (NS) | B
Coppoolse, 1999 | 21 | III | 100 | LLE at 60% of W_max_; 5/wk for 8 wk + Edu | LLE at 90% of W_max_ (1 min) and 45% of W_max_ (2min); 3/wk for 8 wk, (also received continuous at 60% of W_max_ 2/wk for 8wk) + Edu | 19 (90) | - Maximal exercise capacity ICET: -5 W (NS) | B
Kaelin, 1999 (Abstract) | 19 | IV | 89 | LLE; 3/wk for 6 wk + Edu; BE; Psy; Rel | LLE (active to rest ratio 2:1); + Edu; BE; Psy; Rel | 13 (68) | - Functional exercise capacity, 6MWT: 41m (-17, 99) | C
Additional trial, published after the Puhan et al. systematic review
Vogiatzis, 2005 | 19 | III | 62 | LLE up to 70% of W_max_; 2/wk for 12 wk + Edu; BE; Psy; Rel | LLE up to 140% of W_max_ (30 s) and 45% of W_max_ (30 s) + Edu; BE; Psy; Rel | 19 (100) | - Maximal exercise capacity, ICET: 1W (-25, 27) | B

Trials ordered by worsening COPD severity and then sample size.

BE: breathing exercises; CRDQ: chronic respiratory disease questionnaire; Edu: education; ICET: incremental cycle ergometry test; LLE: lower limb exercise; M: males; N_a_: number analyzed; N_r_: number randomized; NS: not significant; Psy: psychosocial intervention; Rel: relaxation techniques; ULE: upper limb exercise; W: Watt(s); wk: week(s); W_max_: maximum workload.

## Overview and conclusions on the efficacy and safety of pulmonary rehabilitation

There is little evidence available on the efficacy and safety of PR on diseases other than COPD. In fact, only two trials on other diseases (a trial on idiopathic bronchiectasis and a trial on patients with a variety of diagnoses who were weaning from mechanical ventilation) were eligible according to the inclusion criteria we employed. Their results were similar to the findings of trials on COPD patients. There is also very limited evidence on safety outcomes. There is insufficient information from randomized evidence to compare different PR components. With notable exceptions27;45;46 almost all included trials were small and potentially underpowered to detect small changes. The majority of the analyzed trials did not report quality items like the randomization method, efforts to conceal patient allocation, efforts to blind the test assessors to intervention, or power analyses. Almost universally, analyses were not by intention-to-treat. Patient follow-up was very short in most trials, and high attrition rates were often observed. Moreover, several trials reported results in figures only, necessitating electronic digitizing from the printed graph, which unavoidably introduced inaccuracies in the quantitative estimates. Finally, the primary trials routinely did not report correlations between the assessed outcomes. This information might be useful, given that the majority of these outcomes are not independent.

Basing a systematic review on existing published systematic reviews poses several challenges. Individual trials may have to be excluded because of differences in eligibility criteria. Updating may also be complicated because it is often difficult to capture the exact inclusion and exclusion criteria of the primary reviews. Individual systematic reviews use different RCT quality scoring systems. Despite efforts to standardize, inconsistencies may persist. The analysis approach may also be variable: In the two systematic reviews by Puhan et al. the primary reviewers decided not to combine heterogeneous trials, whereas we performed meta-analyses using random effects models. We added or subtracted trials from the Cochrane review meta-analyses according to our criteria, and we performed different subgroup analyses than those of the Cochrane review. Allowing for these caveats, it is unlikely that the aforementioned challenges would invalidate our results.

### Efficacy of exercise-based pulmonary rehabilitation versus conventional care

Existing evidence indicates that exercise-based PR interventions are efficacious in the short term. Fewer trials have assessed long term efficacy outcomes, and their results are in agreement with the short term findings. As noted above, almost all eligible trials pertained to patients with stable COPD or patients after acute exacerbations of COPD.

More specifically, exercise-based PR improves patients' quality of life, maximal and functional exercise capacity beyond what would be expected by chance. Especially in the short term, the improvements in three domains of the CRDQ instrument (namely dyspnea, fatigue and mastery) and in the 6MWT were significantly greater than the minimal clinically significant differences in these outcomes. There is no evidence that the benefits of PR are translated into survival differences, at least among people with stable COPD. This is not surprising, given that few RCT extended follow-up beyond 12 months, and deaths are just too sparse in the short term to detect a statistically significant difference. However, exercise-based PR interventions may reduce hospitalizations and primary care consultations. We believe that the existing RCT suffice to appreciate the the short-term efficacy of exercise-based PR, at least in COPD.

There is also evidence favoring the efficacy of exercise-based PR among patients who are recovering from, or recently recovered from acute exacerbations of COPD. In fact the claimed effects in the health-related quality of life and exercise capacity outcomes are even larger in this patient subgroup. This may be ascribed to the fact that PR accelerates the participants' recovery. An alternative explanation would be that a “hedonistic treadmill” phenomenon has been observed, especially for quality of life outcomes: Health-related quality of life may be very dismally perceived during the acute illness, and an “overcorrection” in this perception might be observed as soon as the overall condition improves. Mortality and hospital re-admissions appear to decrease with exercise-PR based interventions after acute COPD exacerbations. We caution that all these results are from a few small trials with methodological shortcomings, and thus they might be overestimations of the true effects. Larger RCT are needed to confirm these findings.

### Safety of exercise-based pulmonary rehabilitation versus conventional care

Data on safety were very sparsely reported. This paucity of data should not be viewed as evidence of absence of adverse events.

Overall, little is known about the harms associated with PR interventions and which comorbid conditions predispose patients to or protect them from these adverse events. It is anticipated that many comorbid conditions are present in older COPD patients who undergo pulmonary rehabilitation. However, the eligible studies provided little information on the presence of such comorbidities in the studied populations. As expected, patients with serious comorbidities that might have affected the ability of the patients to exercise (unstable cardiac disease, orthopedic and musculoskeletal disease, malignancies etc.) were routinely excluded from PR trials.

### Relative value of different exercise training protocols and of different pulmonary rehabilitation components

Our analysis focused on comparisons with exercise training, and we did not assess the effects on non-exercise components versus no intervention. Overall, information is limited, and based on trials of very small sample sizes. We should caution that the absence of statistically significant differences does not imply that the compared protocols are equivalent. Sample sizes are just too small and the enrolled RCT were not designed to assess equivalence or non-inferiority.

More specifically, there seems to be no formally significant difference between exercise protocols that are tailored to address each patient's specific weaknesses and exercise protocols that are common for all patients. Similarly, there was no evidence in favor of repeated PR interventions, or additional interventions employed to maintain the effects of PR. Poor quality trials reported that supervised and hospital based PR may be advantageous over unsupervised and community or home-based PR, respectively.

Strength training was not consistently associated beyond chance with more favorable outcomes compared to endurance training in the trials that directly compared the two training modalities. This was true when strength training was compared with combined strength and endurance training in a different set of RCT. Interval training protocols may be another option to the continuous training protocols that are usually employed. Finally, there were no RCT that were applicable to the Medicare population of interest that compared high and low intensity training.

Sparse data suggested that exercise training tended to have an additive impact when added to non-exercise PR components like education and/or psychosocial interventions, at least for health-related quality of life. Compared with education alone, exercise and education confer additional benefits in health-related quality of life (total CRDQ) and functional exercise capacity in subjects with moderate functional limitation resulting from dyspnea. The clinical significance of the observed differences was unclear, mainly because of small sample sizes. The same was true when exercise-only PR is contrasted with non-exercise interventions (i.e., IMT, education, breathing, phone follow-up). Because of small sample sizes, very few significant differences were observed.

Finally, we did not find statistically significant differences when we assessed combined exercise training and non-exercise components (i.e., IMT, activity training and lecture series) versus exercise training alone. However, these results should be regarded as proof of equivalence between the compared interventions. They should be viewed with caution because of the limited sample sizes and the questionable methodologic validity of many of the included trials.