# References

1 Pulmonary rehabilitation-1999. American Thoracic Society. Am J Respir Crit Care Med. 1999;159(5 Pt 1):1666-1682. [pmid: 10228143].
2 Nici L, Donner C, Wouters E, Zuwallack R, Ambrosino N, Bourbeau J, et al. American Thoracic Society/European Respiratory Society statement on pulmonary rehabilitation. Am J Respir Crit Care Med. 2006;173(12):1390-1413. [pmid: 16760357].
3 Pulmonary rehabilitation: joint ACCP/AACVPR evidence-based guidelines. ACCP/AACVPR Pulmonary Rehabilitation Guidelines Panel, American College of Chest Physicians, American Association of Cardiovascular and Pulmonary Rehabilitation. Chest. 1997;112(5):1363-1396. [pmid: 9367481].
4 Pulmonary rehabilitation. Thorax. 2001;56(11):827-834. [pmid: 11641505].
5 Hill NS. Pulmonary rehabilitation. Proc Am Thorac Soc. 2006;3(1):66-74. [pmid: 16493153].
6 Lacasse Y, Wong E, Guyatt GH, King D, Cook DJ, Goldstein RS. Meta-analysis of respiratory rehabilitation in chronic obstructive pulmonary disease. [see comment]. Lancet. 1996;348(9035):1115-1119. [pmid: 8888163].
7 Lacasse Y, Brosseau L, Milne S, Martin S, Wong E, Guyatt GH, et al. Pulmonary rehabilitation for chronic obstructive pulmonary disease. Cochrane Database Syst Rev. 2002;(3). CD003793.
8 Lacasse Y, Guyatt GH, Goldstein RS. The components of a respiratory rehabilitation program: a systematic overview. [see comment]. Chest. 1997;111(4):1077-1088. [pmid: 9106590].
9 Puhan MA, Schunemann HJ, Frey M, Scharplatz M, Bachmann LM. How should COPD patients exercise during respiratory rehabilitation? Comparison of exercise modalities and intensities to treat skeletal muscle dysfunction. Thorax. 2005;60(5):367-375. [pmid: 15860711].
10 Puhan MA, Scharplatz M, Troosters T, Steurer J. Respiratory rehabilitation after acute exacerbation of COPD may reduce risk for readmission and mortality -- a systematic review. Respir Res. 2005;6(1):54. [pmid: 15943867].
11 Celli BR, Cote CG, Marin JM, Casanova C, Montes de OM, Mendez RA, et al. The body-mass index, airflow obstruction, dyspnea, and exercise capacity index in chronic obstructive pulmonary disease. [see comment]. New England Journal of Medicine. 2004;350(10):1005-1012. [pmid: 14999112].
12 Pauwels RA, Buist AS, Calverley PM, Jenkins CR, Hurd SS. Global strategy for the diagnosis, management, and prevention of chronic obstructive pulmonary disease. NHLBI/WHO Global Initiative for Chronic Obstructive Lung Disease (GOLD) Workshop summary. Am J Respir Crit Care Med. 2001;163(5):1256-1276. [pmid: 11316667].
13 Mahler DA, Wells CK. Evaluation of clinical methods for rating dyspnea. Chest. 1988;93(3):580-586. [pmid: 3342669].
14 Guyatt GH, Berman LB, Townsend M, Pugsley SO, Chambers LW. A measure of quality of life for clinical trials in chronic lung disease. Thorax. 1987;42(10):773-778. [pmid: 3321537].
15 Jones PW, Quirk FH, Baveystock CM, Littlejohns P. A self-complete measure of health status for chronic airflow limitation. The St. George's Respiratory Questionnaire. Am Rev Respir Dis. 1992;145(6):1321-1327. [pmid: 1595997].
16 The Handbook of Research Synthesis. New York. Russell Sage Foundation. 1994.
17 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177-188. [pmid: 3802833].
18 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002;21(11):1539-1558. [pmid: 12111919].
19 Knapp G, Hartung J. Improved tests for a random effects meta-regression with a single covariate. Stat Med. 2003;22(17):2693-2710. [pmid: 12939780].
20 Salman GF, Mosier MC, Beasley BW, Calkins DR. Rehabilitation for patients with chronic obstructive pulmonary disease: meta-analysis of randomized controlled trials. [see comment]. Journal of General Internal Medicine. 2003;18(3):213-221. [pmid: 12648254].
21 Cambach W, Wagenaar RC, Koelman TW, van Keimpema AR, Kemper HC. The long-term effects of pulmonary rehabilitation in patients with asthma and chronic obstructive pulmonary disease: a research synthesis. Archives of Physical Medicine & Rehabilitation. 1999;80(1):103-111. [pmid: 9915381].
22 Chavannes N, Vollenberg JJ, van Schayck CP, Wouters EF. Effects of physical activity in mild to moderate COPD: a systematic review. Br J Gen Pract. 2002;52(480):574-578. [pmid: 12120732].
23 Sin DD, McAlister FA, Man SF, Anthonisen NR. Contemporary management of chronic obstructive pulmonary disease: scientific review. JAMA. 2003;290(17):2301-2312. [pmid: 14600189].
24 Busch AJ, McClements JD. Effects of a supervised home exercise program on patients with severe chronic obstructive pulmonary disease. Physical Therapy. 1988;68(4):469-474. [pmid: 3353456].
25 Cambach W, Chadwick-Straver RV, Wagenaar RC, van Keimpema AR, Kemper HC. The effects of a community-based pulmonary rehabilitation programme on exercise tolerance and quality of life: a randomized controlled trial. European Respiratory Journal. 1997;10(1):104-113. [pmid: 9032501].
26 Goldstein RS, Gort EH, Stubbing D, Avendano MA, Guyatt GH. Randomised controlled trial of respiratory rehabilitation. [see comment]. Lancet. 1994;344(8934):1394-1397. [pmid: 7968075].
27 Griffiths TL, Burr ML, Campbell IA, Lewis-Jenkins V, Mullins J, Shiels K, et al. Results at 1 year of outpatient multidisciplinary pulmonary rehabilitation: a randomised controlled trial. [see comment][erratum appears in Lancet 2000 Apr 8;355(9211):1280 Note: Lonescu AA [corrected to Ionescu AA]]. Lancet. 2000;355(9201):362-368. [pmid: 10665556].
28 Hernandez MT, Rubio TM, Ruiz FO, Riera HS, Gil RS, Gomez JC. Results of a home-based training program for patients with COPD. Chest. 2000;118(1):106-114. [pmid: 10893367].
29 Simpson K, Killian K, McCartney N, Stubbing DG, Jones NL. Randomised controlled trial of weightlifting exercise in patients with chronic airflow limitation. Thorax. 1992;47(2):70-75. [pmid: 1549826].
30 Troosters T, Gosselink R, Decramer M. Short- and long-term effects of outpatient rehabilitation in patients with chronic obstructive pulmonary disease: a randomized trial. American Journal of Medicine. 2000;109(3):207-212. [pmid: 10974183].
31 Wijkstra PJ, van AR, Kraan J, Otten V, Postma DS, Koeter GH. Quality of life in patients with chronic obstructive pulmonary disease improves after rehabilitation at home. European Respiratory Journal. 1994;7(2):269-273. [pmid: 8162979].
32 Emery CF, Schein RL, Hauck ER, MacIntyre NR. Psychological and cognitive outcomes of a randomized trial of exercise among patients with chronic obstructive pulmonary disease. Health Psychology. 1998;17(3):232-240. [pmid: 9619472].
33 Engstrom CP, Persson LO, Larsson S, Sullivan M. Long-term effects of a pulmonary rehabilitation programme in outpatients with chronic obstructive pulmonary disease: a randomized controlled study. Scandinavian Journal of Rehabilitation Medicine. 1999;31(4):207-213. [pmid: 10599897].
34 Guell R, Casan P, Belda J, Sangenis M, Morante F, Guyatt GH, et al. Long-term effects of outpatient rehabilitation of COPD: A randomized trial. Chest. 2000;117(4):976-983. [pmid: 10767227].
35 Jones DT, Thomson RJ, Sears MR. Physical exercise and resistive breathing training in severe chronic airways obstruction--are they effective?. Eur J Respir Dis. 1985;67(3):159-166. [pmid: 4076354].
36 Lake FR, Henderson K, Briffa T, Openshaw J, Musk AW. Upper-limb and lower-limb exercise training in patients with chronic airflow obstruction. Chest. 1990;97(5):1077-1082. [pmid: 2184993].
37 McGavin CR, Gupta SP, Lloyd EL, McHardy GJ. Physical rehabilitation for the chronic bronchitic: results of a controlled trial of exercises in the home. Thorax. 1977;32(3):307-311. [pmid: 882944].
38 Strijbos JH, Postma DS, van AR, Gimeno F, Koeter GH. A comparison between an outpatient hospital-based pulmonary rehabilitation program and a home-care pulmonary rehabilitation program in patients with COPD. A follow-up of 18 months. [see comment]. Chest. 1996;109(2):366-372. [pmid: 8620707].
39 Strijbos JH, Postma DS, van AR, Gimeno F, Koeter GH. Feasibility and effects of a home-care rehabilitation program in patients with chronic obstructive pulmonary disease. Journal of Cardiopulmonary Rehabilitation. 1996;16(6):386-393. [pmid: 8985797].
40 Vallet G, Varray A, Fontaine JL, Prefaut C. Value of individualized rehabilitation at the ventilatory threshold level in moderately severe chronic obstructive pulmonary disease. Rev Mal Respir. 1994;11(5):493-501. [pmid: 7816993].
41 Booker HA. Exercise training and breathing control in patients with chronic airflow limitation. Physiotherapy. 1984;70(7):258-260. [pmid: 6379707].
42 Ringbaek TJ, Broendum E, Hemmingsen L, Lybeck K, Nielsen D, Andersen C, et al. Rehabilitation of patients with chronic obstructive pulmonary disease. Exercise twice a week is not sufficient!. Respiratory Medicine. 2000;94(2):150-154. [pmid: 10714421].
43 Bendstrup KE, Ingemann JJ, Holm S, Bengtsson B. Out-patient rehabilitation improves activities of daily living, quality of life and exercise tolerance in chronic obstructive pulmonary disease. European Respiratory Journal. 1997;10(12):2801-2806. [pmid: 9493664].
44 Wijkstra PJ, ten VERGERT EM, van AR, Otten V, Kraan J, Postma DS, et al. Long term benefits of rehabilitation at home on quality of life and exercise tolerance in patients with chronic obstructive pulmonary disease. Thorax. 1995;50(8):824-828. [pmid: 7570431].
45 Bourbeau J, Julien M, Maltais F, Rouleau M, Beaupre A, Begin R, et al. Reduction of hospital utilization in patients with chronic obstructive pulmonary disease: a disease-specific self-management intervention. [see comment]. Archives of Internal Medicine. 2003;163(5):585-591. [pmid: 12622605].
46 Gadoury MA, Schwartzman K, Rouleau M, Maltais F, Julien M, Beaupre A, et al. Self-management reduces both short- and long-term hospitalisation in COPD. European Respiratory Journal. 2005;26(5):853-857. [pmid: 16264046].
47 Finnerty JP, Keeping I, Bullough I, Jones J. The effectiveness of outpatient pulmonary rehabilitation in chronic lung disease: a randomized controlled trial. Chest. 2001;119(6):1705-1710. [pmid: 11399694].
48 Singh V, Khandelwal DC, Khandelwal R, Abusaria S. Pulmonary rehabilitation in patients with chronic obstructive pulmonary disease. Indian Journal of Chest Diseases & Allied Sciences. 2003;45(1):13-17. [pmid: 12683707].
49 Kirsten DK, Taube C, Lehnigk B, Jorres RA, Magnussen H. Exercise training improves recovery in patients with COPD after an acute exacerbation. Respiratory Medicine. 1998;92(10):1191-1198. [pmid: 9926148].
50 Behnke M, Taube C, Kirsten D, Lehnigk B, Jorres RA, Magnussen H. Home-based exercise is capable of preserving hospital-based improvements in severe chronic obstructive pulmonary disease. Respiratory Medicine. 2000;94(12):1184-1191. [pmid: 11192954].
51 Behnke M, Jorres RA, Kirsten D, Magnussen H. Clinical benefits of a combined hospital and home-based exercise programme over 18 months in patients with severe COPD. Monaldi Archives for Chest Disease. 2003;59(1):44-51. [pmid: 14533282].
52 Man WD, Polkey MI, Donaldson N, Gray BJ, Moxham J. Community pulmonary rehabilitation after hospitalisation for acute exacerbations of chronic obstructive pulmonary disease: randomised controlled study. [see comment]. BMJ. 2004;329(7476):1209. [pmid: 15504763].
53 Murphy N, Bell C, Costello RW. Extending a home from hospital care programme for COPD exacerbations to include pulmonary rehabilitation. Respir Med. 2005;99(10):1297-1302. [pmid: 16140230].
54 Nava S. Rehabilitation of patients admitted to a respiratory intensive care unit. Archives of Physical Medicine & Rehabilitation. 1998;79(7):849-854. [pmid: 9685104].
55 Troosters T, Gosselink R, De Paepe K. Pulmonary rehabilitation improves survival in COPD patients with a recent severe acute exacerbation. Am J Respir Crit Care Med. 2002;165:A16.
56 Witek TJ Jr, Mahler DA. Minimal important difference of the transition dyspnoea index in a multinational clinical trial. Eur Respir J. 2003;21(2):267-272. [pmid: 12608440].
57 Ram FS, Robinson SM, Black PN. Effects of physical training in asthma: a systematic review. Br J Sports Med. 2000;34(3):162-167. [pmid: 10854014].
58 Bradley J, Moran F, Greenstone M. Physical training for bronchiectasis. Cochrane Database Syst Rev. 2002;(3). CD002166.
59 Newall C, Stockley RA, Hill SL. Exercise training and inspiratory muscle training in patients with bronchiectasis. [see comment]. Thorax. 2005;60(11):943-948. [pmid: 15994254].
60 Porta R, Vitacca M, Gile LS, Clini E, Bianchi L, Zanotti E, et al. Supported arm training in patients recently weaned from mechanical ventilation. Chest. 2005;128(4):2511-2520. [pmid: 16236917].
61 Wijkstra PJ, van der Mark TW, Kraan J, van AR, Koeter GH, Postma DS. Long-term effects of home rehabilitation on physical performance in chronic obstructive pulmonary disease. American Journal of Respiratory & Critical Care Medicine. 1996;153(4:Pt 1). t-41.
62 Sewell L, Singh SJ, Williams JE, Collier R, Morgan MD. Can individualized rehabilitation improve functional independence in elderly patients with COPD?. Chest. 2005;128(3):1194-1200. [pmid: 16162706].
63 Elliott M, Watson C, Wilkinson E, Musk AW, Lake FR. Short- and long-term hospital and community exercise programmes for patients with chronic obstructive pulmonary disease. Respirology. 2004;9(3):345-351. [pmid: 15363006].
64 Puente-Maestu L, Sanz ML, Sanz P, Cubillo JM, Mayol J, Casaburi R. Comparison of effects of supervised versus self-monitored training programmes in patients with chronic obstructive pulmonary disease. European Respiratory Journal. 2000;15(3):517-525. [pmid: 10759446].
65 Puente-Maestu L, Sanz ML, Sanz P, Ruiz de Ona JM, Rodriguez-Hermosa JL, Whipp BJ. Effects of two types of training on pulmonary and cardiac responses to moderate exercise in patients with COPD. European Respiratory Journal. 2000;15(6):1026-1032. [pmid: 10885420].
66 Foglio K, Bianchi L, Ambrosino N. Is it really useful to repeat outpatient pulmonary rehabilitation programs in patients with chronic airway obstruction? A 2-year controlled study. Chest. 2001;119(6):1696-1704. [pmid: 11399693].
67 Berry MJ, Rejeski WJ, Adair NE, Ettinger WH Jr, Zaccaro DJ, Sevick MA. A randomized, controlled trial comparing long-term and short-term exercise in patients with chronic obstructive pulmonary disease. Journal of Cardiopulmonary Rehabilitation. 2003;23(1):60-68. [pmid: 12576914].
68 Brooks D, Krip B, Mangovski-Alzamora S, Goldstein RS. The effect of postrehabilitation programmes among individuals with chronic obstructive pulmonary disease. [see comment]. European Respiratory Journal. 2002;20(1):20-29. [pmid: 12166571].
69 Foy CG, Rejeski WJ, Berry MJ, Zaccaro D, Woodard CM. Gender moderates the effects of exercise therapy on health-related quality of life among COPD patients. Chest. 2001;119(1):70-76. [pmid: 11157586].
70 Ries AL, Kaplan RM, Myers R, Prewitt LM. Maintenance after pulmonary rehabilitation in chronic lung disease: a randomized trial. American Journal of Respiratory & Critical Care Medicine. 2003;167(6):880-888. [pmid: 12505859].
71 Bestall JC, Paul EA, Garrod R, Garnham R, Jones RW, Wedzicha AJ. Longitudinal trends in exercise capacity and health status after pulmonary rehabilitation in patients with COPD. Respiratory Medicine. 2003;97(2):173-180. [pmid: 12587969].
72 Larson JL, Covey MK, Wirtz SE, Berry JK, Alex CG, Langbein WE, et al. Cycle ergometer and inspiratory muscle training in chronic obstructive pulmonary disease. American Journal of Respiratory & Critical Care Medicine. 1999;160(2):500-507. [pmid: 10430720].
73 Wedzicha JA, Bestall JC, Garrod R, Garnham R, Paul EA, Jones PW. Randomized controlled trial of pulmonary rehabilitation in severe chronic obstructive pulmonary disease patients, stratified with the MRC dyspnoea scale. European Respiratory Journal. 1998;12(2):363-369. [pmid: 9727786].
74 Bauldoff GS, Hoffman LA, Sciurba F, Zullo TG. Home-based, upper-arm exercise training for patients with chronic obstructive pulmonary disease. Heart & Lung. 1996;25(4):288-294. [pmid: 8836744].
75 Berry MJ, Adair NE, Sevensky KS, Quinby A, Lever HM. Inspiratory muscle training and whole-body reconditioning in chronic obstructive pulmonary disease. American Journal of Respiratory & Critical Care Medicine. 1996;153(6:Pt 1). t-6.
76 Ries AL, Moser KM. Comparison of isocapnic hyperventilation and walking exercise training at home in pulmonary rehabilitation. Chest. 1986;90(2):285-289. [pmid: 3731904].
77 Dekhuijzen PN, Folgering HT, van Herwaarden CL. Target-flow inspiratory muscle training during pulmonary rehabilitation in patients with COPD. Chest. 1991;99(1):128-133. [pmid: 1984942].
78 Goldstein R, De RJ, Long S, Dolmage T, Avendano MA. Applicability of a threshold loading device for inspiratory muscle testing and training in patients with COPD. Chest. 1989;96(3):564-571. [pmid: 2766815].
79 Mador MJ, Deniz O, Aggarwal A, Shaffer M, Kufel TJ, Spengler CM. Effect of respiratory muscle endurance training in patients with COPD undergoing pulmonary rehabilitation. Chest. 2005;128(3):1216-1224. [pmid: 16162709].
80 McKeon JL, Turner J, Kelly C, Dent A, Zimmerman PV. The effect of inspiratory resistive training on exercise capacity in optimally treated patients with severe chronic airflow limitation. Australian & New Zealand Journal of Medicine. 1986;16(5):648-652. [pmid: 3469962].
81 Norweg AM, Whiteson J, Malgady R, Mola A, Rey M. The effectiveness of different combinations of pulmonary rehabilitation program components: a randomized controlled trial. Chest. 2005;128(2):663-672. [pmid: 16100152].
82 Wanke T, Formanek D, Lahrmann H, Brath H, Wild M, Wagner C, et al. Effects of combined inspiratory muscle and cycle ergometer training on exercise performance in patients with COPD. [see comment]. European Respiratory Journal. 1994;7(12):2205-2211. [pmid: 7713205].
83 Weiner P, Azgad Y, Ganam R. Inspiratory muscle training combined with general exercise reconditioning in patients with COPD. Chest. 1992;102(5):1351-1356. [pmid: 1424850].
84 Chen H, Dukes R, Martin BJ. Inspiratory muscle training in patients with chronic obstructive pulmonary disease. American Review of Respiratory Disease. 1985;131(2):251-255. [pmid: 3970455].
85 O'Shea SD, Taylor NF, Paratz J. Peripheral muscle strength training in COPD: a systematic review. Chest. 2004;126(3):903-914. [pmid: 15364773].
86 Casaburi R, Patessio A, Ioli F, Zanaboni S, Donner CF, Wasserman K. Reductions in exercise lactic acidosis and ventilation as a result of exercise training in patients with obstructive lung disease. Am Rev Respir Dis. 1991;143(1):9-18. [pmid: 1986689].
87 Patessio A, Carone M, Ioli F, Donner CF. Ventilatory and metabolic changes as a result of exercise training in COPD patients. Chest. 1992;101(5:Suppl). Suppl-278S.
88 Vallet G, Ahmaidi S, Serres I, Fabre C, Bourgouin D, Desplan J, et al. Comparison of two training programmes in chronic airway limitation patients: standardized versus individualized protocols. Eur Respir J. 1997;10(1):114-122. [pmid: 9032502].
89 Bernard S, Whittom F, LeBlanc P, Jobin J, Belleau R, Berube C, et al. Aerobic and strength training in patients with chronic obstructive pulmonary disease. American Journal of Respiratory & Critical Care Medicine. 1999;159(3):896-901. [pmid: 10051269].
90 Normandin EA, McCusker C, Connors M, Vale F, Gerardi D, ZuWallack RL. An evaluation of two approaches to exercise conditioning in pulmonary rehabilitation. Chest. 2002;121(4):1085-1091. [pmid: 11948036].
91 Ortega F, Toral J, Cejudo P, Villagomez R, Sanchez H, Castillo J, et al. Comparison of effects of strength and endurance training in patients with chronic obstructive pulmonary disease. American Journal of Respiratory & Critical Care Medicine. 2002;166(5):669-674. [pmid: 12204863].
92 Ries AL, Ellis B, Hawkins RW. Upper extremity exercise training in chronic obstructive pulmonary disease. Chest. 1988;93(4):688-692. [pmid: 3349825].
93 Sivori M, Rhodius E, Kaplan P, Talarico M, Gorojod G, Carreras B, et al. Exercise training in chronic obstructive pulmonary disease. Comparative study of aerobic training of lower limbs vs. combination with upper limbs. Medicina (B Aires). 1998;58(6):717-727. [pmid: 10347965].
94 Spruit MA, Gosselink R, Troosters T, De PK, Decramer M. Resistance versus endurance training in patients with COPD and peripheral muscle weakness. European Respiratory Journal. 2002;19(6):1072-1078. [pmid: 12108859].
95 Wurtemberger G, Bastian K. Functional effects of different training in patients with COPD. Pneumologie. 2001;55(12):553-562. [pmid: 11748505].
96 Coppoolse R, Schols AM, Baarends EM, Mostert R, Akkermans MA, Janssen PP, et al. Interval versus continuous training in patients with severe COPD: a randomized clinical trial. European Respiratory Journal. 1999;14(2):258-263. [pmid: 10515398].
97 Results of 6 minute ambulation and met tolerance of patients with severe chronic obstructive pulmonary disease using two different aerobic training regimens: interval training vs. continuous training. American Society of Exercise Physiology 2nd Annual Meeting. 1997.
98 Vogiatzis I, Nanas S, Roussos C. Interval training as an alternative modality to continuous exercise in patients with COPD. [see comment]. European Respiratory Journal. 2002;20(1):12-19. [pmid: 12166558].
99 Vogiatzis I, Terzis G, Nanas S, Stratakos G, Simoes DC, Georgiadou O, et al. Skeletal muscle adaptations to interval training in patients with advanced COPD. Chest. 2005;128(6):3838-3845. [pmid: 16354852].