# Methods

This technology assessment is based on a systematic review of the literature. We retrieved published systematic reviews and meta-analyses, whenever such were available to identify potential relevant studies. A MEDLINE search was conducted to identify additional RCT that address questions not covered by the systematic reviews, or that update existing eligible systematic reviews.

## Definitions

Disease severity was defined for COPD only. It was not defined for other diseases because of the dearth of RCT on other diseases. The BODE index (body-mass index (B), degree of airflow obstruction (O) and dyspnea (D), and exercise capacity (E), measured by the 6 minute walk test) is a composite 10 point score that was proposed in 2004 to predict clinical deterioration and survival in people with COPD.11 However, the vast majority of the retrieved research was completed before its introduction. We therefore classified COPD severity according to the GOLD classification scheme.12 Because patient level data were not available, we based our classification on the average FEV_1_ values in each RCT. Hence, GOLD I was FEV_1_≥80% of predicted; GOLD II 80%>FEV_1_≥50% of predicted; GOLD III 50%>FEV_1_≥30% of predicted; and GOLD IV <30% of predicted. When absolute FEV_1_ values instead of proportions were given, we considered that FEV_1_<1.0L would fall in the GOLD IV category, and that the boundary between GOLD II and III would be 1.5L.

We defined a trial as long term if it followed patients for 12 months or more. We characterized PR programs of more than 12 weeks duration as long duration interventions.

## Search strategy

We conducted a comprehensive search in MEDLINE from its inception through April 25, 2006 to identify English language publications of RCT, systematic reviews, and meta-analyses of PR among adults. Search terms included the following pulmonary disease terms: lung diseases,chronic obstructive pulmonary disease, asthma, bronchiectasis, lung transplantation, and artificial respiration; and the relevant PR interventions terms: rehabilitation, exercise therapy, exercise movement techniques, exercise tolerance, and physical therapy modalities; and the relevant study designs (for details refer to the complete search strategy in appendix A).

## Inclusion and exclusion criteria

After consultation with the technical expert, AHRQ and CMS, we considered all research publications meeting the criteria described in the following sections. We considered all relevant RCT and systematic reviews and meta-analyses. We did not review RCT that were published only as abstracts, or meta-analyses in which all of the included RCT were published as abstracts. Papers published in languages other than English were also excluded (unless they were included in a systematic review along with trials published in English).

### Patient population

Eligible research reports focused on patient groups with mean age of 59 years or older, who had COPD or another chronic respiratory disease of interest such as asthma, lung cancer, bronchiectasis, interstitial lung disease (idiopathic) and chest wall disease. We excluded perioperative PR interventions (defined as less than 3 months before or after a major operation such as abdominal or chest surgery), post-polio syndrome and muscular dystrophies, patients with tetraplegia/spinal injury, patients with cystic fibrosis and patients with more rare diseases unlikely to impact on a population level (e.g., lung disease in scleroderma).

### Intervention

We considered eligible research where the intervention was an exercise-based PR intervention and consisted of 2 weeks or longer of any exercise training for large skeletal muscles with at least two sessions per week, with or without any non-exercise PR component. The comparator could be any intervention. We excluded all research where exercise–based PR had not been administered in any patient group. We excluded trials in which the intervention was “passive” training of large skeletal muscles with electrical stimulation, or where the experimental intervention was yoga or tai chi exercises.

### Comparisons of interest

We considered eligible research that addressed the following comparison schemes:

- Exercise training ± non-exercise PR component(s) compared with conventional care.
  Here conventional care would be usual community care for patients with stable chronic disease, or conventional treatment for patients in the respiratory care unit weaning from ventilator dependency. Whenever we encountered RCT with more than two arms, the arm with the more comprehensive PR intervention (exercise training plus the more non-exercise PR components and/or IMT) was compared with conventional care.
- Exercise training + non-exercise PR component(s) compared with the same non-exercise PR component(s), or
  Exercise training compared with non-exercise PR component(s), or
  Exercise-based PR + non-exercise PR component(s) compared with the same type of exercise-based PR
  From these comparison schemes we excluded RCT where the non-exercise PR components were supplemental interventions. These were defined as pharmacological (including O_2_ supplementation during exercise, tiotropium administration during the PR etc), nutritional (e.g.,polyunsaturated fatty acids administration) or other interventions (e.g.,ventilation support) aiming to facilitate or enhance the effects of exercise training. CMS deemed that the comparison of PR with supplemental interventions versus PR without supplemental interventions does not need to be assessed, on the basis that supplemental treatments are largely non-covered and cannot easily be covered by Medicare.
- Exercise-based PR with a given exercise training protocol compared with same PR with different exercise training protocol with respect to the following parameters:
  ○ General exercises compared with PR with individually targeted exercise: Whether all patients received the same exercises versus whether patients received specific exercises that addressed their personal weaknesses or needs.
  ○ Setting of the PR intervention (home; community; hospital).
  ○ Whether intervention was supervised by a health care professional versus the same intervention unsupervised.
  ○ The intensity of exercise training: Whether patients exercised at levels ≥60% of their personal maximum workload (higher intensity) versus lower intensity exercise, while keeping the other exercise training characteristics (frequency and duration) reasonably similar.
  ○ Endurance versus strength training: Exercise training protocol included only endurance training (aerobic exercises) versus protocols that included only strength training, or added strength training to endurance training.
  ○ Continuous exercise versus interval exercise training: Whether exercises were performed in a continuous manner at a given, constant intensity versus exercise training consisting of brief bouts of high (or maximal) intensity exercise separated by periods of lower intensity exercise (or rest).
  Especially for the last three factors (i.e., high or low intensity, endurance or strength and continuous or interval training) we required that all exercise training protocols be standardized, as previously suggested.9 Standardized exercise was defined as identical exercise training schemes (treadmill walking, cycle ergometer or weightlifting training) at intensities that are objectively measurable (e.g., in Watts). For example outdoor walking “at a quiet pace” would not qualify as standardized exercise training.
- After the end of an exercise based PR intervention, presence compared with absence of repeated PR or other maintenance strategy.

### Eligible outcomes

Outcomes were assessed at longest follow-up, unless otherwise stated.

#### Effectiveness and efficacy

Where applicable, we focused on the description of outcome measures in their natural units (e.g., meters, Watts, minutes), rather than relative percentage changes from an average reference value. Main metric of interest was the difference in the changes from baseline for continuous measures and the odds ratio or the risk ratio for binary outcomes. We selected the following outcomes as important in the evaluation of the effectiveness or efficacy of exercise-based PR:

- The main dyspnea-specific outcome was the baseline dyspnea index/transitional dyspnea index (BDI/TDI) score.13 Other were the Visual Analog Scale (VAS), the modified Borg scale, and the Chronic Respiratory Disease Questionnaire (CRDQ) dyspnea domain score.14
- Disease specific Quality of Life (QoL) outcomes: the four domains of CRDQ (dyspnea, mastery, fatigue, emotion)14 and the total score in St George's Respiratory disease Questionnaire (SGRQ).15
- Exercise capacity was measured as
  ○ maximal exercise capacity (reported outcomes on incremental exercise tests like incremental cycle ergometry test, ICET, incremental treadmill walking and incremental shuttle walking test [ISWT] results) with main outcome the maximal workload, W_max_
  ○ functional/endurance exercise capacity (e.g.,6 minute walk test [6MWT] results, as distance in meters walked in 6 minutes).
  ○ endurance at constant work rate (e.g., endurance time at 50% of maximal exercise capacity in a treadmill walking test)
  Note that the assessment of maximum exercise capacity with incremental protocols on a cycle ergometer or a treadmill, as well as the assessment of endurance capacity with constant work rate tests on a cycle ergometer or a treadmill are “laboratory-based” tests. In contrast the 6MWD and the ISWT that assess the functional capacity are mainly “field-based” tests, conducted outside the laboratory.
- General outcomes include all cause mortality; and (re)admission rates.
- Inspiratory capacity

#### Safety

Adverse events, as defined in the primary reports, and all cause mortality were considered as a safety outcome. All safety outcomes were assessed at longest available follow-up.

Dropouts are clearly related to the efficacy of the interventions. Patients who perceive the treatment as non-efficacious may opt to leave the study early. Dropouts are also influenced by many practical and logistic issues (e.g., personal time required for study participation, transportation issues, loss of interest), and therefore were not used as a proxy for adverse events or as a safety outcome.

#### Outcomes not analyzed

PR cannot reverse the derangement of pulmonary mechanics (as assessed by FEV_1_, other lung volumes and lung capacities) and this is especially true for COPD.1;3;4 Thus, changes in pulmonary physiologic measurements were not reviewed; a possible exception was the lungs' inspiratory capacity (IC), which was suggested by the technical expert as a potentially useful index with direct clinical meaning for people with COPD.

We decided not to review changes in other, additional physiological measurements, despite the fact that they may convey valuable ergophysiological or other specialized information. Thus, after discussions with the technical expert, we concluded that we would not review quantities like the maximum inspiratory pressure (PI_max_), maximum expiratory pressure (PE_max_), endurance time of respiratory muscles, heart rate, respiratory frequency, peak O_2_ uptake during exercise, muscle strength, muscle thickness or other similar quantities.

## Meta-analyses and subgroup or sensitivity analyses

We performed meta-analyses whenever two or more trials where available on the same question, regardless of the extent or significance of between-study heterogeneity. We combined continuous measurements using inverse variance random effects models.16 The summary continuous effect sizes were expressed as weighted mean differences (WMD) expressed in their natural units. For binary outcomes we combined odds ratios or risk ratios using the DerSimonian and Laird random effects method.17 Random effects models allow for between-study heterogeneity (dissimilarity) in the meta-analyses and incorporate it in the calculations. We tested for heterogeneity in meta-analyses with Cochran's Q statistic (considered significant at p<0.10 16) and quantified its extent with the I^2^ statistic.18 I^2^ ranges between 0 and 100% and higher values imply greater heterogeneity.

We performed subgroup analyses with respect to several factors mentioned below. These were implemented in a random effects meta-regression framework,19 provided that more than 5 trials were available, so as to avoid overfitting. We hypothesized that trials with higher internal validity may be associated with less impressive findings in the outcomes of interest (RCT with blinded versus non-blinded assessors; RCT with quality grading A versus B or C [see section below on quality grading]). We also assessed in meta-regressions the following factors, which we considered possibly associated with better outcomes: interventions with duration longer than 12 weeks versus interventions of 12 weeks or less; interventions including non-exercise PR components versus exercise training only; supervised versus unsupervised PR; home-based versus in- or out-patient exercise training; and patients with moderate disease (GOLD II and III) versus patients with severe disease (GOLD IV). We considered that there was evidence for subgroup effects only when the meta-regressions yielded statistically significant inferences.

Where applicable, we performed sensitivity analyses by excluding RCT published in languages other than English and assessing whether inferences changed. For some papers where numerical information was given in figures, rather than text or tables, we extracted the needed information by electronically digitizing the corresponding plots with specialized software (Engauge digitizer ver 2.12, Mark Mitchell). Meta-analyses were performed in Intercooled Stata 8.2 (Stata Corp. College Station, TX)

## Selection of systematic reviews to address key questions

In discussions with AHRQ and CMS we decided to capitalize on existing systematic reviews and meta-analyses, provided that they did not have serious methodological flaws, and that they addressed at least one of the comparisons we have delineated in the inclusion/exclusion criteria in an eligible patient subgroup (see below on the assessment of existing systematic reviews). Using these systematic reviews/meta-analyses as a starting basis, we reviewed any additional relevant RCT published after these systematic reviews. We retrieved the individual RCT described in the systematic reviews and perused them to clarify important details when needed.

The identified systematic reviews and meta-analyses of RCT were critically evaluated. We required that eligible systematic reviews assessed comparisons similar to the ones delineated in our inclusion and exclusion criteria. High quality systematic reviews had a clearly described and sufficiently thorough search strategy (ideally searching more than one electronic databases and using an alternative searching algorithm such as hand searching of selected journals); had clearly described inclusion and exclusion criteria; had assessed the internal and external validity of the reviewed RCT according to standard, published methods; clearly described the methods used for meta-analysis and appropriately employed them; and reached conclusions supported by their data. If more than one such systematic reviews or meta-analyses were identified, we retained the one that was reported in greater detail and addressed specific questions that were closer to our key questions.

## Assessing individual randomized controlled trials

### Applicability and quality of randomized controlled trials

The applicability of RCT was assessed based on disease spectrum, the setting of the interventions (outpatient or home-based rather than inpatient for non-critically ill patients), the gender distribution of the participants, and the selection criteria of the individual RCT (presence of a run-in period; focus on patient subgroups). The inclusion criteria ensured that the average age of the participants was similar to that of the Medicare population.

We assessed the methodological quality of RCT based on whether or not they clearly reported specific quality items: description of randomization, blinding of test assessors (blinding of patients is not feasible), concealment of patient allocation, presence of ad-hoc power analyses, and description and magnitude of attrition rates. We classified the methodological quality of RCT in to a three-point scale (A, B, C or good, moderate, poor, respectively, as described below). For RCT described in systematic reviews, we relied on the reviewers' assessments, and translated them in our three-point scale.

Grade A (good methodological quality) studies fulfill most commonly held concepts of high quality, including the following: a formal randomized study; clear description of the population, setting, intervention and comparison groups; appropriate measurement of outcomes; appropriate statistical and analytic methods and reporting; no reporting errors; not excessive dropouts (<20%); clear reporting of dropouts; and no obvious bias.

Grade B (moderate methodological quality) studies may be susceptible to some bias, but not sufficient to invalidate the results. Such studies do not meet the criteria described in category A. They have some deficiencies but none likely to cause major bias. Study may be missing information making assessment of the limitations and potential problems difficult.

Grade C (poor methodological quality) studies are subject to significant bias that may invalidate the results. Such studies may have serious errors in design, analysis or reporting. These studies may have large amounts of missing information or discrepancies in reporting.

## Evidence tables and summary tables of reviewed randomized controlled trials

Evidence tables for all eligible RCT that were individually reviewed are provided in Appendix D.

We constructed summary tables that capture the important information from the included meta-analyses and RCT.