# Background

Pulmonary rehabilitation (PR) has been defined in a 1999 joint statement of the American Thoracic Society (ATS) and the European Respiratory Society (ERS) as a “multi-disciplinary program of care for patients with chronic respiratory impairment that is individually tailored and designed to optimize physical and social performance and autonomy”.1 The recent update of that statement considers PR as an “evidence-based, multidisciplinary, and comprehensive intervention for patients with chronic respiratory diseases who are symptomatic and often have decreased daily life activities. Integrated into the individualized treatment of the patient, pulmonary rehabilitation is designed to reduce symptoms, optimize functional status, increase participation, and reduce health care costs through stabilizing or reversing systemic manifestations of the disease”.2

PR interventions consist at minimum of some form of exercise training, and most commonly of a variety of additional interventions (education, breathing exercises and respiratory muscle training, nutritional interventions, psychosocial support). The aim of PR is to improve the perceived health-related quality of life (HRQOL) of patients with chronic lung diseases by reducing the severity of their symptoms, their disability and handicap, and by improving their functional independence.1;3-5

Patients with chronic lung disease, especially patients with chronic obstructive pulmonary disease (COPD) may experience marked dyspnea and intolerance to exercise.1;5 It is postulated that these symptoms of lung disease are also related to the patients' generalized weakness and their comorbidities (e.g., cor pulmonale; heart failure, renal failure, etc).1;5 Dyspnea in turn results in reduced activity, which worsens and perpetuates muscle weakness, and a vicious cycle between muscle de-conditioning and shortness of breath is established. This is especially true for ambulatory muscles. In addition, many everyday tasks are performed using upper limb and torso (shoulder, neck and abdominal) muscles, some of which act as accessory respiratory muscles. During such tasks the reduced contribution of accessory respiratory muscles to ventilation may intensify shortness of breath. Notwithstanding symptoms directly related to exertion, patients with chronic respiratory disease may experience depression, anxiety and social isolation.

PR has been employed in the attempt to reverse some of these aforementioned pathophysiological and psychosocial conditions. Exercise training aims to improve muscle strength and endurance, and to optimize their use by the patients. It is also hypothesized to decrease general fatigue. Participation in PR programs is expected to reduce anxiety and social isolation. This may be a result of the anti-depressive effects of exercise, and of the beneficial role of education and other interventions apart from exercise training.

The major national and international respiratory organizations (ATS/ERS,1;2 the American College of Chest Physicians [ACCP] jointly with the American Association of Cardiovascular and Pulmonary Rehabilitation [AACVPR],3 and Global initiative for chronic Obstructive Lung Disease [GOLD, www.goldcopd.com]) have recommended PR as the standard of care in the treatment of moderate to severe chronic respiratory disease.

A large number of randomized controlled trials (RCT) have been reported on PR interventions in participants relevant to the Medicare population. The majority of these trials evaluated patients with COPD. There is a dearth of evidence for exercise-based PR (randomized trials in particular) on patients with other lung diseases. The role of non-exercise components of PR interventions has not been extensively studied in COPD patients.

## Statement of work

The Center for Medicare and Medicaid Services (CMS) has requested a technology assessment through the Agency for Healthcare Research and Quality (AHRQ) on PR primarily for COPD and conditions such as asthma, bronchiectasis, ventilator dependency, and other relevant respiratory illness. The objective is to address specific questions about safety and effectiveness of PR. There seems to be limited evidence on safety and effectiveness of PR for other conditions of interest, apart from COPD. Also, the evidence of PR effectiveness in the elderly has not been systematically evaluated. Specific components of PR and subgroups of patients eligible for PR are also of interest to CMS.

The overarching question of interest to CMS is: What is the evidence for safety and effectiveness of PR for patients ≥65 years old with COPD, asthma, bronchiectasis and other relevant conditions? CMS is also interested in a description of the outcomes measures reported in the studies, a summary of the evidence on complications, harms, and adverse events associated with PR that have been reported, and an assessment on whether conditions prevalent in the older Medicare population increase the risk for these events with PR. Specific factors of interest to CMS include:

a. Internal and external validity of the studies (includes inclusion and exclusion criteria of the studies).
b. Length of follow-up
c. Intensity of treatment, number and frequency of sessions
d. Patient characteristics (i.e., gender, comorbidity) and disease characteristics (i.e., disease severity). Age of patients and generalizability to Medicare population.
e. Concurrent treatment with β-agonists and/or hormonal treatments and/or new therapies (e.g., spiriva) and/or concurrent treatment with supplementary oxygen
f. Concurrent PR in disease management programs
g. Place of delivery (e.g., home, inpatient, outpatient).
h. Physician supervision
i. Components of the PR and whether components were individually tailored or generalized
j. Persistence of benefits/harms over time
k. Repeated course of PR

## Adopted terminology for pulmonary rehabilitation and its components

Exercise training is commonly perceived as the cornerstone of PR, and is considered by many a sine-qua-non for PR interventions.1;3;5-10 In this technology assessment we define and adopt the following terms:

- Exercise training is any intervention that focuses on endurance or strength training of large skeletal muscles, like upper limb and lower limb muscles. Distinct types of exercise training interventions exist. “Passive” training of large skeletal muscles with electrostimulation is not included in the definition of exercise training.
- Inspiratory muscle training (IMT) refers to training of the inspiratory muscles through resistance breathing, threshold breathing or isocapnic hyperpnea (volume training). Based on expert input and CMS input, IMT is the only form of respiratory muscle training that was assessed.
- Non-exercise PR components stand for educational, psychosocial or behavioral interventions (alone or in combinations).
- Conventional care is a broad term. It refers to the care that different patient subgroups receive in current clinical practice. Conventional care is different for people with stabilized disease compared with patients after an acute exacerbation of chronic disease. For example, patients in respiratory intensive care units may routinely receive some form of exercise training during weaning from ventilators.
- Usual community care refers to the conventional care that non-hospitalized patients with chronic respiratory diseases receive in current clinical practice, and implies absence of interventions with exercise training and/or non-exercise components.
- Exercise-based PR refers to any PR intervention that at minimum has an exercise-training component. Exercise-based PR may include non-exercise PR components or other supplemental interventions on top of exercise training.

## Delineation of key questions and specific tasks

We reorganized the statement of work into specific Key Questions (and subquestions). The influence of the “factors” (study-level or patient-level characteristics) mentioned in the statement of work on the efficacy of PR interventions can be assessed directly and indirectly. The indirect assessment compares RCT of PR with a “control” intervention with respect to a specific factor (e.g., among RCT of PR versus “control”, contrast those that used high or low intensity of exercise training). The direct assessment is may be more preferable, and pertains to RCT that directly compare different intervention protocols. The direct assessment is applicable only to some of the above factors that refer to variations of PR protocols: One may for example seek RCT that directly compare high and low intensity exercise training. Some of the specific subquestions we have posed emphasize this second option of head-to-head comparison of different PR protocols.

### Key Questions

#### Key Question 1

What is the efficacy and safety of PR for patients in the Medicare population aged ≥65 years who have COPD, asthma, bronchiectasis or other relevant conditions?

All subquestions under the key questions place emphasize specific areas of interest. Subquestions 1.1 to 1.3 can be assessed by RCT that compared exercise-based PR versus conventional care.

KQ1.1 What are the long term effects of PR?
KQ1.2 Is the risk for PR-associated complications, harms and adverse events increased by comorbid conditions prevalent in the older Medicare population?
KQ1.3 Are there patient level features (i.e., characteristics pertaining to individual patients, like gender, diagnosis, cotreatments, and similar) that modify the effect of PR?

The following subquestions (1.4 to 1.7) can be assessed by specific RCT that compare different protocols of exercise-based PR. We pose them to facilitate organizing:

KQ1.4 What is the efficacy and safety of PR with general exercises compared with PR with individually targeted exercise?
KQ1.5 What is the efficacy and safety of PR interventions that are located in different settings (home-based, outpatient, inpatient), and of supervised compared with unsupervised PR?
KQ1.6 What is the efficacy and safety of repeated programs of PR?
KQ1.7 What is the efficacy and safety of long term maintenance interventions for PR?

#### Key Question 2

What is the efficacy and safety of specific PR components in exercise-based PR interventions? There are many subquestions that could be posed, because there are many different combinations of PR components. With input from CMS we decided to focus on comparisons where exercise training was part of at least one of the comparators. Thus, we assess the value of non-exercise components with respect to exercise training. We use comparison schemes that, in principle, allow the isolation of the effects of different PR components.

Based on the above, we devised the following specific subquestions, which can be assessed by specific RCT to facilitate organization:

KQ2.1 What is the incremental efficacy and safety of exercise training when added to non-exercise PR components? (assessed by comparison 1 in Table 1)
KQ2.2 What is the efficacy and safety of exercise training compared with other non-exercise PR components? (assessed by comparison 2 in Table 1)
KQ2.3 What is the incremental efficacy and safety of non-exercise PR components when added to exercise-based PR? (assessed by comparison 3 in Table 1)
KQ2.4 What is the efficacy and safety of different modes of exercise training, specifically:
  a. Higher versus lower intensity training?
  b. Endurance versus strength exercise training?
  c. Continuous versus interval training?
  (assessed by comparison 4 in Table 1)

Table 1 Classification of the different comparison schemes selected for evaluation

Comparison | Comparator A | Comparator B | This comparison provides answers on:
1 | Exercise training + non-exercise PR component(s) | Same non-exercise PR component(s) | Exercise training. Assesses the incremental effect of exercise training
2 | Exercise training | Non-exercise PR component | Head-to-head comparison
3 | Exercise-based PR + non-exercise PR component(s) | Same exercise-based PR | Non-exercise PR component(s). Assesses the incremental effect of non-exercise PR component to an exercised-based PR program.
4 | Exercise training protocol with characteristic A (see comments column) | Exercise training protocol with characteristic B | Different exercise training protocols: Higher or lower intensity of training; endurance or strength training; and continuous or interval training