# Evidence tables for randomized controlled trials not included in the published systematic reviews used in this report

Bauldoff 1996

Berry 1996

Berry 2003 and Foy 2001

Bourbeau 2003 and 2005 (2 papers)

Brooks 2002

Chen 1985

Dekhuizen 1991

Elliott 2004

Emery 1998

Finnerty 2001

Foglio 2001

Goldstein 1989

Larson 1999

Mador 2005

McKeon 1896

Newall 2005

Norweg 2005

Porta 2006

Puente-Maestu 2000 (2 papers)

Ries 1986

Ries 2003

Sewell 2005

Singh 2003

Vogiatzis 2005, (RefID 28)

Wanke 1994 (Ref ID 1558)

Wedzicha 1998 and Bestall 2003 (2 papers)

Weiner 1992 (1734)

Wijkstra 1996