# The Jadad quality scale

The Jadad quality scale1 was used in the Cochrane review that formed the basis of our reply to question 1. The reader should note that the Jadad scale was not used in the rest of the review.

The Jadad scale is a 3 item/5question scale:

1. Randomization:
  a. Is the study described as randomized?
  b. Is the randomization adequately described/properly generated?
2. Masking:
  a. Is the study described as double blinded?
  b. Is the control treatment described as indistinguishable?
3. Dropouts:
  a. Is there a description of withdrawals?

The total scores range from 0 to 5 points, where trials with 0-2 points are considered to be of poor quality, and those with 3-5 points represent higher quality RCT.1

However, as mentioned in the text, pulmonary rehabilitation interventions cannot be double-blinded, and this limits the maximum number of points an RCT can get in the Jadad scale. Thus the applicability of the Jadad scale to RCT in pulmonary rehabilitation interventions is limited. Moreover, it is well appreciated that the use of summary scores from quality scales is problematic. The results are very dependent on the choice of the scale and thus it may be challenging to interpret them. The methodological literature on these topics is extensive.

## References to Appendix C

1 Jadad AR, Moore RA, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: Is blinding necessary?. Controlled Clin Trials. 1996;17:1-12. [pmid: 8721797].