# Comments on validated outcomes

Pulmonary rehabilitation interventions change the everyday routine of the COPD patients, and generally demand their cooperation and commitment. Similarly, PR interventions require substantial effort from the health care providers and may represent a sizable financial burden. It is therefore very important to assess their efficacy and/or effectiveness using validated outcome measures. Ideally, outcomes ought to be reproducible, sensitive to changes in the measured quantities, to correlate well with the targeted (measured) quantities, and to convey clinically useful information.1

We briefly describe and discuss outcome measures for which the minimal clinically significant difference has been estimated. Absolute changes in these outcomes can therefore be perceived as clinically significant or not.

## Chronic Respiratory Disease Questionnaire (CRDQ)

The CRDQ has been extensively used in the literature and there is considerable experience from its use.2 The instrument has four components:

- dyspnoea (assessed in 5 activities the patient deems important). Possible range: 5 to 35
- fatigue (regarding physical function). Possible range: 4 to 28
- emotional function (anxiety, depression). Possible range: 7 to 49
- mastery of breathing (sense of control over disease): Possible range: 4 to 28.

The CRDQ is interviewer-rated and the minimum clinically significant difference is 0.5 points on a 7 point scale.2 Higher scores are optimal. We have converted CRDQ data on a seven point scale when needed (by dividing the corresponding domains by 5, 4, 7, or 4).

## St George's Respiratory disease Questionnaire (SGRQ)

The SGRD instrument is a self-administered 76-item questionnaire (53 questions).3 The instrument assesses three main areas.

- Symptoms (sputum, coughing, wheezing, dyspnoea)
- Activity
- Impact of disease on daily life

Higher scores imply worst health. The minimum clinically significant difference is 4 units. Dyspnoea is assessed as part of the symptoms domain, but not separately.

## 6 minute walk test (6MWT)

The 6MWT assesses functional exercise capacity.4 The patient is instructed to walk for six minutes on zero slope on a standard route, usually back and forth between two signs. The result of the test is the total distance covered in 6 minutes. It has been shown that the minimal clinically significant difference in the test is approximately 50 meters (54 meters).4 Differential encouragement may have a great impact on test performance, approximately 30 meters on average (30.4 meters).5 For this reason it is suggested that standardized encouraging comments should be given by the test supervisor to the patients during testing. It has also been claimed that the 6MWT should be taken three times and the best performance should be recorded.6 It has also been shown that outdoor and hallway testing may yield different results.7 The above are described in detail in the ATS guidelines for the 6MWT.8

## References to Appendix B

### Reference List

1 Pashkow P, Ades PA, Emery CF, Frid DJ, Houston-Miller N, Peske G, et al. Outcome measurement in cardiac and pulmonary rehabilitation. AACVPR Outcomes Committee. American Association of Cardiovascular and Pulmonary Rehabilitation. J Cardiopulm Rehabil. 1995;15(6):394-405. [pmid: 8624964].
2 Guyatt GH, Berman LB, Townsend M, Pugsley SO, Chambers LW. A measure of quality of life for clinical trials in chronic lung disease. Thorax. 1987;42(10):773-778. [pmid: 3321537].
3 Jones PW, Quirk FH, Baveystock CM, Littlejohns P. A self-complete measure of health status for chronic airflow limitation. The St. George's Respiratory Questionnaire. Am Rev Respir Dis. 1992;145(6):1321-1327. [pmid: 1595997].
4 Redelmeier DA, Bayoumi AM, Goldstein RS, Guyatt GH. Interpreting small differences in functional status: the Six Minute Walk test in chronic lung disease patients. Am J Respir Crit Care Med. 1997;155(4):1278-1282. [pmid: 9105067].
5 Guyatt GH, Pugsley SO, Sullivan MJ, Thompson PJ, Berman L, Jones NL, et al. Effect of encouragement on walking test performance. Thorax. 1984;39(11):818-822. [pmid: 6505988].
6 Steele B. Timed walking tests of exercise capacity in chronic cardiopulmonary illness. J Cardiopulm Rehabil. 1996;16(1):25-33. [pmid: 8907439].
7 Stevens D, Elpern E, Sharma K, Szidon P, Ankin M, Kesten S. Comparison of hallway and treadmill six-minute walk tests. Am J Respir Crit Care Med. 1999;160(5 Pt 1):1540-1543. [pmid: 10556117].
8 ATS statement: guidelines for the six-minute walk test. Am J Respir Crit Care Med. 2002;166(1):111-117. [pmid: 12091180].