# Detailed search strategy

The following search strategy was used (formulated for OVID MEDLINE)

1. exp lung diseases/
2. exp asthma/
3. exp pulmonary disease, chronic obstructive/
4. exp bronchiectasis/
5. exp respiration, artificial/
6. exp lung transplantation/
7. obstructive pulmonary disease$.tw.
8. COPD.tw.
9. or/1-8
10. exp rehabilitation/
11. exp exercise therapy/
12. rehabilit$.mp.
13. exp Exercise Movement Techniques/
14. exp exercise tolerance/
15. exp physical therapy modalities/
16. rh.fs.
17. or/10-16
18. 9 and 17
19. follow-up studies/
20. (follow-up or followup).tw.
21. exp Case-Control Studies/
22. (case adj20 control).tw.
23. exp Longitudinal Studies/
24. longitudinal.tw.
25. exp Cohort Studies/
26. cohort.tw.
27. (random$ or rct).tw.
28. exp Randomized Controlled Trials/
29. exp random allocation/
30. exp Double-Blind Method/
31. exp Single-Blind Method/
32. randomized controlled trial.pt.
33. clinical trial.pt.
34. controlled clinical trials/
35. (clin$ adj trial$).tw.
36. ((singl$ or doubl$ or trebl$ or tripl$) adj (blind$ or mask$)).tw.
37. exp PLACEBOS/
38. placebo$.tw.
39. exp Research Design/
40. exp Evaluation Studies/
41. exp Prospective Studies/
42. exp Comparative Study/
43. or/19-42
44. 18 and 43
45. limit 44 to humans
46. limit 45 to english language
47. limit 46 to (addresses or bibliography or biography or case reports or congresses or consensus development conference or consensus development conference, nih or dictionary or directory or festschrift or government publications or guideline or interview or lectures or legal cases or legislation or news or newspaper article or patient education handout or periodical index or practice guideline or “review”)
48. 46 not 47
49. limit 46 to (editorial and comment)
50. limit 46 to (letter and comment)
51. limit 46 to (editorial and letter)
52. or/49-51
53. limit 52 to clinical trial
54. 52 not 53
55. 46 not (47 or 54)
56. limit 55 to “all adult (19 plus years)”
57. 55 not 56
58. limit 57 to “all child (0 to 18 years)”
59. 55 not 58