# GLOSSARY

ACE: angiotensin converting enzyme
ACS: acute coronary syndrome
AMI: acute myocardial infarction
CAD: coronary artery disease
CMS: Centers for Medicare & Medicaid Services
CT: computed tomography
CVD: cardiovascular disease
IVUS: intravenous ultrasound
MI: myocardial infarction
MRI: magnetic resonance imaging
OCT: optical coherence tomography
PTCA: percutaneous transluminal coronary angioplasty
US: ultrasound
VP: vulnerable plaque