# REFERENCES

AbuRahma AF, Kyer PD 3rd, Robinson PA, et al. The correlation of ultrasonic carotid plaque morphology and carotid plaque hemorrhage: clinical implications. Surgery. 1998;124:721-726. [pmid: 9780994].
Alderman EL, Corley SD, Fisher LD, et al. Five-year angiographic follow-up of factors associated with progression of coronary artery disease in the coronary artery surgery study (CASS). J Am Coll Cardiol. 1993;22:1141-1154. [pmid: 8409054].
Ambrose JA, Tannenbaum MA, Alexopoulos D, et al. Angiographic progression of coronary artery disease and the development of myocardial infarction. J AM Col Cardiol. 1988;12:56-62.
Ambrose JA, Martinez EE. A new paradigm for plaque stabilization. Circulation. 2002;105:2000-2004. [pmid: 11997290].
Anonymous. Spotting heart attacks in the making. CBSNEWS.com. 2002. Sept. 20.
Anonymous. Vulnerable plaque diagnosis, treatment: Is enrollment “impossible”?. The Gray Sheet. Sept. 2003;29(39):23.
Biasucci LM, Liuzzo G, Fantuzzi G, et al. Increasing levels of interleukin (IL)–1Ra and IL–6 during the first 2 days of hospitalization in unstable angina are associated with increased risk of in-hospital coronary events. Circulation. 1999;99:2079-2084. [pmid: 10217645].
Biasucci LM, Liuzzo G, Grillo RL, et al. Elevated levels of C–reactive protein at discharge in patients with unstable angina predict recurrent instability. Circulation. 1999;99:855-860. [pmid: 10027805].
Blake GJ, Ridker PM. Inflammatory mechanisms in atherosclerosis: from laboratory evidence to clinical application. Ital Heart J. 2001;2:796-800. [pmid: 11770860].
Blankenberg S, Rupprecht HJ, Bickel C, et al. Circulating cell adhesion molecules and death in patients with coronary artery disease. Circulation. 2001;104:1336-1342. [pmid: 11560847].
Blankenberg S, Rupprecht HJ, Poirier O, et al. Plasma concentrations and genetic variation of matrix metalloproteinase 9 and prognosis of patients with cardiovascular disease. Circulation. 2003;107:1579-1585. [pmid: 12668489].
Blankenberg S, Tiret L, Bickel C, et al. Interleukin-18 is a strong predictor of cardiovascular death in stable and unstable angina. Circulation. 2002;106:24-30. [pmid: 12093765].
Blum JE, Handmaker H. Plenary session: Friday imaging symposium: role of small-peptide radiopharmaceuticals in the evaluation of deep venous thrombosis. Radiographics. 2000;20:1187-1193. 1999. [pmid: 10903709].
Botnar RM, Stuber M, Kissinger KV, et al. Noninvasive coronary vessel wall and plaque imaging with magnetic resonance imaging. Circulation. 2000;102:2582-2587. [pmid: 11085960].
Brennan JF, Romer TJ, Lees RS, et al. Determination of human coronary artery composition by Raman spectroscopy. Circulation. 1997;96:99-105. [pmid: 9236423].
Callister TQ, Raggi P, Cooil B, et al. Effect of HMG-CoA reductase inhibitors on coronary artery disease as assessed by electron-beam computed tomography. N Engl J Med. 1998;339:1972-1978. [pmid: 9869668].
Cassells W, Hathorn B, David M, et al. Thermal detection of cellular infiltrates in living atherosclerotic plaques: possible implications for plaque rupture and thrombosis. Lancet. 1996;347:1447-1451. [pmid: 8676628].
Cassis LA, Lodder RA. Near-IR imaging of atheromas in living arterial tissue. Anal Chem. 1993;65:1247-1256. [pmid: 8503505].
Chakhtoura EY, Shamoon FE, Haft JI, et al. Comparison of platelet activation in unstable and stable angina pectoris and correlation with coronary angiographic findings. Am J Cardiol. 2000;86:835-839. [pmid: 11024397].
Chester MR, Chen L, Kaski JC. The natural history of unhealed complex coronary plaques. J Am Coll Cardiol. 1996;28:604-608. [pmid: 8772746].
Cohen A, Tzourio C, Bertrand B, et al. Aortic plaque morphology and vascular events: a followup study in patients with ischemic stroke. Circulation. 1997;96:3838-3841. [pmid: 9403605].
Corti R, Fayad ZA, Fuster V, et al. Effects of lipid-lowering by simvastatin on human atherosclerotic lesions: a longitudinal study by high-resolution, noninvasive magnetic resonance imaging. Circulation. 2001;104:249-252. [pmid: 11457739].
Corti R, Badimon JJ. Biologic aspects of vulnerable plaque. Curr Opin Cardiol. 2002;17:616-625. [pmid: 12466704].
Corti R, Farkouh ME, Badimon JJ. The vulnerable plaque and acute coronary syndromes. Am J Med. 2002;113:668-680. [pmid: 12505118].
Danesh J, Whincup P, Walker M, et al. Low grade inflammation and coronary heart disease: prospective study and updated meta-analyses. BMJ. 2000;321:199-204. [pmid: 10903648].
Davies MJ. A macro and micro view of coronary vascular insult in ischemic heart disease. Circulation. suppl II. 1990;82:38-46.
Davies MJ. The composition of coronary artery plaques. N Engl J Med. 1997;336:1312-1314. [pmid: 9113937].
de Korte CL, van der Steen AF, Cepedes EI, et al. Characterization of plaque components and vulnerability with intravascular ultrasound elastography. Phys Med Biol. 2000;45:1465-1475. [pmid: 10870704].
de Lemos JA, Hennekens CH, Ridker PM. Plasma concentration of soluble vascular cell adhesion molecule-1 and subsequent cardiovascular risk. J Am Coll Cardiol. 2000;36:423-426. [pmid: 10933352].
Fayad ZA, Fuster V, Fallon JT, Jayasundera T, Worthley SG, Helft G, Aguinaldo JG, Badimon JJ, Sharma SK. Noninvasive in vivo human coronary artery lumen and wall imaging using black-blood magnetic resonance imaging. Circulation. 2000;102:506-510. [pmid: 10920061].
Fayad ZA, Fuster V. Clinical imaging of the high-risk or vulnerable atherosclerotic plaque. Circ Res. 2001;89:305-316. [pmid: 11509446].
Falk E, Shah PK, Fuster V. Coronary plaque disruption. Circulation. 1995;92:657-671. [pmid: 7634481].
Forrester JS. Prevention of plaque rupture: a new paradigm of therapy. Ann Intern Med. 2002;137:823-833. [pmid: 12435220].
Fujimoto J, Boppart S, Tearney G, et al. High resolution in vivo intra-arterial imaging with optical coherence tomography. Heart. 1999;82:128-133. [pmid: 10409522].
Gerdes N, Sukhova GK, Libby P, et al. Expression of interleukin (IL)–18 and functional IL–18 receptor on human vascular endothelial cells, smooth muscle cells, and macrophages: implications for atherogenesis. J Exp Med. 2002;195:245-257. [pmid: 11805151].
Glagov S, Weisenberg E, Zarins CK, et al. Compensatory enlargement of human atherosclerotic coronary arteries. N Engl J Med. 1987;316:1371-1375. [pmid: 3574413].
Goldstein JA, Demetriou D, Grines CL, et al. Multiple complex coronary plaques in patients with acute myocardial infarction. N Engl J Med. 2000;343:915-922. [pmid: 11006367].
Goldstein JA. Angiographic plaque complexity: The tip of the unstable plaque iceberg. J Am Col Cardiol. 2002;39:1464-1467.
Haft JI, Al-Zarka AM, Newark NJ. Comparison of the natural history of irregular and smooth coronary lesions: insights into the pathogenesis, progression, and prognosis of coronary atherosclerosis. Am Heart J. 1993;126:551-561. [pmid: 8362708].
Haverkate F, Thompson SG, Pyke SD, et al. Production of C-reactive protein and risk of coronary events in stable and unstable angina: European Concerted Action on Thrombosis and Disabilities Angina Pectoris Study Group. Lancet. 1997;349:462-466. [pmid: 9040576].
Haverkate F. C-reactive protein as cardiovascular risk factor. A discovery by ECAT. Clin Chem Lab Med. 2000;38:1055. [pmid: 11140623].
Heeschen C, Hamm CW, Bruemmer J, et al. Predictive value of C-reactive protein and troponin T in patients with unstable angina: a comparative analysis. CAPTURE Investigators. Chimeric c7E3 AntiPlatelet Therapy in Unstable angina Refractory to standard treatment trial. J Am Coll Cardiol. 2000;35:1535-1542. [pmid: 10807457].
Hofmann LV, Bluemke DA, Lawler B, et al. Intravascular MRI of peripheral arteries feasibility study for imaging of arterial pathology. Circulation. suppl II. 2001;104:375.
Hwang SJ, Ballantyne CM, Sharrett AR, et al. Circulating adhesion molecules VCAM–1, ICAM–1, and E-selectin in carotid atherosclerosis and incident coronary heart disease cases: the Atherosclerosis Risk In Communities (ARIC) study. Circulation. 1997;96:4219-4225. [pmid: 9416885].
Iuliano L, Mauriello A, Sbarigia E, et al. Radiolabeled native low-density lipoprotein injected into patients with carotid stenosis accumulates in macrophages of atherosclerotic plaque: effect of vitamin E supplementation. Circulation. 2000;101:1249-1254. [pmid: 10725283].
Kawasaki M, Takatsu H, Noda T, et al. In vivo quantitative tissue characterization of human coronary arterial plaques by use of integrated backscatter intravascular ultrasound and comparison with angioscopic findings. Circulation. 2002;105:2487-2492. [pmid: 12034654].
Kereiakes DJ. The Emperor’s Clothes: In search of the vulnerable plaque. Circulation. 2003;107:2076-2077. [pmid: 12719288].
Koenig W, Sund M, Frohlich M, et al. C-Reactive protein, a sensitive marker of inflammation, predicts future risk of coronary heart disease in initially healthy middle-aged men: results from the MONICA (Monitoring Trends and Determinants in Cardiovascular Disease) Augsburg Cohort Study, 1984 to 1992. Circulation. 1999;99:237-242. [pmid: 9892589].
Kolodgie FD, Burke AP, Farb A, et al. The thin-cap fibroatheroma: a type of vulnerable plaque: The major precursor lesion to acute coronary syndromes. Current Opinion Cardiol. 2001;16:285-292.
Kullo IJ, Edwards WD, Schwartz RS. Vulnerable plaque: pathobiology and clinical implications. Ann Intern Med. 1998;129:1050-1060. [pmid: 9867761].
Kuller LH, Tracy RP, Shaten J, et al. Relation of C-reactive protein and coronary heart disease in the MRFIT nested case-control study. Multiple Risk Factor Intervention Trial. Am J Epidemiol. 1996;144:537-547. [pmid: 8797513].
Kurata T, Kurata M, Okada T. Cerivastatin induces carotid artery plaque stabilization independently of cholesterol lowering in patients with hypercholesterolaemia. J Int Med Res. 2001;29:329-334. [pmid: 11675906].
Lal BK, Hobson RW 2nd, Pappas PJ, et al. Pixel distribution analysis of B-mode ultrasound scan images predicts histologic features of atherosclerotic carotid plaques. J Vasc Surg. 2002;35:1210-1217. [pmid: 12042733].
Libby P, Aikawa M. Evolution and stabilization of vulnerable atherosclerotic plaques. Jap Circulation J. 2001;65:473-479.
Lindmark E, Diderholm E, Wallentin L, et al. Relationship between interleukin 6 and mortality in patients with unstable coronary artery disease: effects of an early invasive or noninvasive strategy. JAMA. 2001;286:2107-2113. [pmid: 11694151].
Little WC, Constantinescu M, Applegate RJ, et al. Can coronary angiography predict the site of a subsequent myocardial infarction in patients with mild to moderate coronary artery disease?. Circulation. 1988;78:1157-1166. [pmid: 3180375].
Liuzzo G, Biasucci LM, Gallimore JR, et al. The prognostic value of C-reactive protein and serum amyloid a protein in severe unstable angina. N Engl J Med. 1994;331:417-424. [pmid: 7880233].
Lowe GD, Yarnell JW, Rumley A, et al. C-reactive protein, fibrin D-dimer, and incident ischemic heart disease in the Speedwell study: are inflammation and fibrin turnover linked in pathogenesis?. Arterioscler Thromb Vasc Biol. 2001;21:603-610. [pmid: 11304479].
MacNeill BD, Lowe HC, Takano M, et al. Intravascular modalities for detection of vulnerable plaque: current status. Arteriosclerosis, Thromb Vasc Biol. 2003;23:1333-1342.
Mann J, Davies MJ. Mechanisms of progression in native coronary artery disease: role of healed plaque disruption. Heart. 1999;82:265-268. [pmid: 10455072].
Mizuno K, Miyamoto A, Satomura K, et al. Angioscopic coronary macromorphology in patients with acute coronary disorders. Lancet. 1991;337:809-812. [pmid: 1672912].
Mizuno K, Satomura K, Miyamoto A, et al. Angioscopic evaluation of coronary-artery thrombi in acute coronary syndromes. N Engl J Med. 1992;326:287-291. [pmid: 1728732].
Monroe VS, Parilak LD, Kerensky RA. Angiographic patterns and the natural history of the vulnerable plaque. Prog Cardiovasc Dis. 2002;44:339-347. [pmid: 12024332].
Moreno PR, Raman Purushothaman K, O’Connor WN, et al. Lack of association between calcification and vulnerability in human atherosclerotic plaques. J Am Coll Cardiol. 2000;35:303a.
Moreno PR, Lodder RA, Purushothaman KR, et al. Detection of lipid pool, thin fibrous cap, and inflammatory cells in human aortic atherosclerotic plaques by near-infrared spectroscopy. Circulation. 2002;105:923-927. [pmid: 11864919].
Morrow DA, Ridker PM. C-reactive protein, inflammation, and coronary risk. Med Clin North Am. 2000;84:149-161. [pmid: 10685132].
Morrow DA, Rifai N, Antman EM, et al. C-reactive protein is a potent predictor of mortality independently of and in combination with troponin T in acute coronary syndromes: a TIMI 11A substudy. Thrombolysis in Myocardial Infarction. J Am Coll Cardiol. 1998;31:1460-1465. [pmid: 9626820].
Naghavi M, Libby P, Falk E, et al. From vulnerable plaque to vulnerable patient: a call for new definitions and risk assessment strategies: Part 1. Circulation. 2003a;108:1664-1672. [pmid: 14530185].
Naghavi M, Libby P, Falk E, et al. From vulnerable plaque to vulnerable patient: a call for new definitions and risk assessment strategies: Part II. Circulation. 2003b;108:1772-1778. [pmid: 14557340].
Nissen SE, Yock P. Intravascular ultrasound: novel pathophysiological insights and current clinical applications. Circulation. 2001;103:604-616. [pmid: 11157729].
Nissen SE, Tsunoda T, Tuzcu EM, et al. Effect of recombinant ApoA-I Milano on coronary atherosclerosis in patients with acute coronary syndromes: a randomized controlled trial. JAMA. 2003;290:2292-2300. [pmid: 14600188].
O'Connor CM, Dunne MW, Pfeffer MA, et al. Azithromycin for the secondary prevention of coronary heart disease events: the WIZARD study: a randomized controlled trial. JAMA. 2003;290:1459-1466. [pmid: 13129985].
Rabbani R, Topol EJ. Strategies to achieve coronary arterial plaque stabilization. Cardiovasc Res. 1999;41:402-417. [pmid: 10341840].
Regar E, Serruys PW. Ten years after introduction of intravascular ultrasound in the catheterization laboratory: tool or toy?. Z Kardiol. 2002;91:89-97. [pmid: 12641021].
Reuben DB, Ferrucci L, Wallace R, et al. The prognostic value of serum albumin in healthy older persons with low and high serum interleukin-6 (IL–6) levels. J Am Geriatrics Soc. 2000;48:1404-1407.
Ridker PM, Cushman M, Stampfer MJ, et al. Inflammation, aspirin, and the risk of cardiovascular disease in apparently healthy men. N Engl J Med. 1997;336:973-979. [pmid: 9077376].
Ridker PM, Rifai N, Pfeffer M, et al. Elevation of tumor necrosis factor-alpha and increased risk of recurrent coronary events after myocardial infarction. Circulation. 2000;101:2149-2153. [pmid: 10801754].
Ridker PM, Rifai N, Pfeffer MA, et al. Inflammation, pravastatin, and the risk of coronary events after myocardial infarction in patients with average cholesterol levels. Cholesterol and Recurrent Events (CARE) Investigators. Circulation. 1998;98:839-844. [pmid: 9738637].
Ridker PM, Stampfer MJ, Rifai N. Novel risk factors for systemic atherosclerosis: a comparison of C-reactive protein, fibrinogen, homocysteine, lipoprotein(a), and standard cholesterol screening as predictors of peripheral arterial disease. JAMA. 2001;285:2481-2485. [pmid: 11368701].
Ridker PM, Cushman M, Stampfer MJ, et al. Plasma concentration of C-reactive protein and risk of developing peripheral vascular disease. Circulation. 1998;97:425-428. [pmid: 9490235].
Ridker PM. High-sensitivity C-reactive protein: potential adjunct for global risk assessment in the primary prevention of cardiovascular disease. Circulation. 2001;103:1813-1818. [pmid: 11282915].
Romer TJ, Brennan JF 3rd, Puppels GJ, et al. Intravascular ultrasound combined with Raman spectroscopy to localize and quantify cholesterol and calcium salts in atherosclerotic coronary arteries. Arterioscler Thromb Vasc Biol. 2000;20:478-483. [pmid: 10669646].
Rothwell P. Evidence of a chronic systemic cause of instability in aterosclerotic plaques. Lancet. 2000;355:19-24. [pmid: 10615886].
Sabatine MS, Morrow DA, de Lemos JA, et al. Multimarker approach to risk stratification in non-ST elevation acute coronary syndromes: simultaneous assessment of troponin I, C-reactive protein, and B-type natriuretic peptide. Circulation. 2002;105:1760-1763. [pmid: 11956114].
Spence JD, Tamayo A, DiCicco M, et al. Unstable carotid plaque. Can Med Assn J. 2002;166:1189.
Schonbeck U, Libby P. The CD40L/CD154 receptor/ligand dyad. Cell Mol Life Sci. 2001;58:4-43. [pmid: 11229815].
Schonbeck U, Varo N, Libby P, et al. Soluble CD40L and cardiovascular risk in women. Circulation. 2001;104:2266-2268. [pmid: 11696462].
Schwartz RS, Bayes-Genis A, Lesser JR, et al. Detecting vulnerable plaque using peripheral blood: inflammatory and cellular markers. J Interven Cardiol. 2003;16:231-242.
Stefanadis C, Diamantopoulos L, Vlachopoulos C, et al. Thermal heterogeneity within human atherosclerotic coronary arteries detected in vivo: a new method of detection by application of a special thermography catheter. Circulation. 1999;99:1965-1971. [pmid: 10208999].
Stefanadis C, Toutouzas K, Vavuranakis M, et al. Statin treatment is associated with reduced thermal heterogeneity in human atherosclerotic plaques. Eur Heart J. 2002;23:1664-1669. [pmid: 12398823].
Stefanadis C, Toutouzas P. In vivo local thermography of coronary artery atherosclerotic plaque in humans. Ann Intern Med. 1998;129:1079-1080. [pmid: 9867775].
Spence JD, Tamayo A, DiCicco M. Unstable carotid plaque. CMAJ. 2002;166:1189. [pmid: 12000255].
Taaffe DR, Harris TB, Ferrucci L, et al. Cross-sectional and prospective relationships of interleukin-6 and C-reactive protein with physical performance in elderly persons: MacArthur studies of successful aging. J Gerontol Series A-Biol Sci Med Sci. 2000;55:M709-M715.
Thies F, Garry JM, Yaqoob P, et al. Association of n-3 polyunsaturated fatty acids with stability of atherosclerotic plaques: a randomised controlled trial. Lancet. 2003;361:477-485. [pmid: 12583947].
Tomoda H, Aoki N. Prognostic value of C-reactive protein levels within six hours after the onset of acute myocardial infarction. Am Heart J. 2000;140:324-328. [pmid: 10925350].
Topol EJ, Nissen SE. Our preoccupation with coronary luminology: the dissociation between clinical and angiographic findings in ischemic heart disease. Circulation. 1995;92:2333-2342. [pmid: 7554219].
Toss H, Lindahl B, Siegbahn A, et al. Prognostic influence of increased fibrinogen and C-reactive protein levels in unstable coronary artery disease. FRISC Study Group. Fragmin during Instability in Coronary Artery Disease. Circulation. 1997;96:4204-4210. [pmid: 9416883].
Toussaint JF, LaMuraglia GM, Southern JF, et al. Magnetic resonance images lipid, fibrous, calcified, hemorrhagic, and thrombotic components of human atherosclerosis in vivo. Circulation. 1996;94:932-938. [pmid: 8790028].
Tracy RP, Lemaitre RN, Psaty BM, et al. Relationship of C-reactive protein to risk of cardiovascular disease in the elderly. Results from the Cardiovascular Health Study and the Rural Health Promotion Project. Arteriosclerosis. Thromb Vasc Biol. 1997;17:1121-1127.
Uchida Y, Nakamura F, Tomaru T, et al. Prediction of acute coronary syndromes by percutaneous coronary angioscopy in patients with stable angina. Am Heart J. 1995;130:195-103. [pmid: 7631596].
Ueda Y, Asakura M, Yamaguchi O, et al. The healing process of infarct-related plaques- insights from 18 months of serial angioscopic follow-up. J Am Coll Cardiol. 2001;38:1916-1922. [pmid: 11738294].
Vallabhajosula S, Fuster V. Atherosclerosis: Imaging techniques and the evolving role of nuclear medicine. J Nucl Med. 1997;38:1788-1796. [pmid: 9374357].
Vallabhajosula S, Paidi M, Badimon JJ, et al. Radiotracers for low density lipoprotein biodistribution studies in vivo: technetium-99m low density lipoprotein versus radioiodinated low density lipoprotein preparations. J Nucl Med. 1988;29:1237-1245. [pmid: 3134523].
Vallabhajosula S. Fuster V, editor. Radioisotopic imaging of atheroma. The Vulnerable Atherosclerotic Plaque: Understanding, Identification and Modification. Armonk, NY. Futura Publishing. 1999:213-229.
Westhuyzen J, Healy H. Review: Biology and relevance of C-reactive protein in cardiovascular and renal disease. Ann Clin Lab Sci. 2000;30:133-143. [pmid: 10807156].
Wexler L, Brundage B, Crouse J, et al. Coronary artery calcification: pathophysiology, epidemiology, imaging methods, and clinical implications. A statement for health professionals from the American Heart Association Writing Group. Circulation. 1996;94:1175-1192. [pmid: 8790070].
Yabushita H, Bouma BE, Houser SL, et al. Characterization of human atherosclerosis by optical coherence tomography. Circulation. 2002;106:1640-1645. [pmid: 12270856].
Yucel EK, Anderson CM, Edelman RR, et al. AHA scientific statement: magnetic resonance angiography: update on applications for extracranial arteries. Circulation. 1999;100:2284-2301. [pmid: 10578005].
Zaman AG, Helft G, Osende JI, et al. Histopathology and pathogenesis of plaque instability and thrombus formation. Drugs Today. 1999;35:641-656. [pmid: 12973427].
Zebrack JS, Muhlestein JB, Horne BD, et al. Intermountain Heart Collaboration Study Group. C-reactive protein and angiographic coronary artery disease: independent and additive predictors of risk in subjects with angina. J Am Coll Cardiol. 2002;39:632-637. [pmid: 11849862].
Zhu Q, Conant E, Chance B. Optical imaging as an adjunct to sonograph in differentiating benign from malignant breast lesions. J Biomed Opt. 2000;5:229-236. [pmid: 10938788].