# SUMMARY

The concept of VP is still evolving. We can only speculate about its course since no studies have been designed to accurately describe the natural history based on plaque characteristics. In such a context it is not surprising that there is only limited inferential evidence regarding methods of diagnosis and treatment modalities of this condition.