# VII REFERENCES CITED

Anderson S.A.; Chinn H.I.; Fisher K.D. 1982. History and current status of infant formulas. Am. J. Clin. Nutr. 35:381–397.7039294
Anderson S.A., editor. 1986. Guidelines for use of dietary intake data. Report prepared for the Food and Drug Administration under Contract No. 223–84-2059 by the Life Sciences Research Office, Federation of American Societies for Experimental Biology, Bethesda, MD. 89p. Available from: FASEB Special Publications Office, Federation of American Societies for Experimental Biology, Bethesda, MD.
Canada, Environmental Health Directorate, Health Protection Branch. 1981. Tapwater consumption in Canada. Catalogue No. H46–2/82–80E (ISBN 0–662-12489–8). Available from: Ministry of National Health and Welfare, Ottawa.
Casady R.J. 1982a. National Center for Health Statistics, Hyattsville, MD. Minimum sample size for the estimation of percentile intervals. Internal memorandum to M.G. Kovar, April 16.
Casady R.J. 1982b. National Center for Health Statistics, Hyattsville, MD. Minimum sample size requirements for the presentation of estimated means, standard errors, standard deviations, and percentiles. Internal memorandum to C. Johnson, June 24.
Cotton L., editor. 1981. Mr. Boston deluxe official bartender's guide. 61st rev. ed. New York: Warner Brothers Books.
Harrell F.E. 1983. PCTL procedure. In: Supplemental libraiy user's guide. SAS User's Group, Inc. Cary, NC: SAS Institute, Inc.
Hartge P.; Cahill J.I.; West D.; Hauck M.; Austin D.; Silverman D.; Hoover R. 1984. Design and methods in a multi-center case-control interview study. Am. J. Public Health 74:52–56.6689843
Hartge P.; Hoover R.; West D.W.; Lyon J.L. 1983. Coffee drinking and risk of bladder cancer. J. Natl. Cancer Inst. 70:1021–1026.6574270
Hodgman C.D.; Weast R.C.; Selby S.M., editors. 1958. Handbook of chemistry and physics. 40th ed. Cleveland: Chemical Rubber Publishing Co.
Hopkin S.M.; Ellis J.C. 1980. Drinking water consumption in Great Britain. Technical Report TR 137. Available from: Water Research Centre, Medmenham Laboratory, Marlow, England.
Japan, Science and Technology Agency, Resources Council. 1984. Standard tables of food composition in Japan. Tokyo.
National Cancer Institute. 1981. Surveillance, epidemiology and end results: incidence and mortality data 1973–77. National Cancer Institute Monograph 57. NIH Publication No. 81–2330. Available from: U.S. Government Printing Office, Washington, DC.
National Center for Health Statistics. 1982. Hematological and nutritional biochemistry reference data for persons 6 months-74 years of age: United States 1976–80. DHHS Publication No. (PHS) 83–1682. Available from: U.S. Government Printing Office, Washington, DC.
National Research Council Food and Board Nutrition. 1980. Recommended dietary allowances. 9th rev. ed. Available from: National Academy of Sciences, Washington, DC.
Pipes P.L. 1981. Nutrition in infancy and childhood. 2nd ed. St. Louis: C.V. Mosby Co.
Randall H.T. 1973. Diet and nutrition in the care of the surgical patient. In: Modern nutrition in health and disease. Goodhart R.S.; Shils M.E., eds. Philadelphia: Lea and Febiger.
Response Analysis Corporation. 1976. Household food use and individual intake: a methodological study. Final report of a study conducted for the Consumer and Food Economics Institute, U.S. Department of Agriculture, Hyattsville, MD.
Rombauer I.S.; Becker M.R. 1975. Joy of cooking. New York: Bobbs-Merrill Co., Inc.
SAS User's Guide. 1985. 5th ed. Cary, NC: SAS Institute, Inc.
Sharrett A.R.; Carter A.P.; Orheim R.M.; Feinleib M. 1982. Daily intake of lead, cadmium, copper and zinc from drinking water: the Seattle study of trace metal exposure. Environ. Res. 28:456–475.7117225
Snedecor G.W.; Cochran W.G. 1967. Statistical methods. 6th ed. Ames, IA: Iowa State University Press.
Swan P.B. 1983. Food consumption by individuals in the United States: two major surveys. Ann. Rev. Nutr. 3:413–432.6357240
U.S. Department of Agriculture. 1963. Composition of foods: raw, processed, prepared. Agricultural Handbook No. 8. Available from: U.S. Government Printing Office, Washington, DC.
U.S. Department of Agriculture. 1976–1986. Composition of foods: raw, processed, prepared. Agricultural Handbooks No. 8–1 through No. 8–16. Available from: U.S. Government Printing Office, Washington, DC.
U.S. Department of Agriculture. 1979. Manual of food codes and conversions of measures to gram-weight for use with individual food intake data from 1977–78 Nationwide Food Consumption Survey. Consumer and Food Economics Administrative Report No. 352. Available from: Human Nutrition Information Service, U.S. Department of Agriculture, Hyattsville, MD.
U.S. Department of Agriculture. 1980. USDA Nutrient Database for Individual Food Intake Surveys. Release 1, 1980. Available from: NTIS, Springfield, VA; PB82–138504/HBF.
U.S. Department of Agriculture. 1980–1981. NFCS 1977–78 Individual Intake Data. Spring, Summer, Fall, and Winter Basic Individual Food Intake Surveys. Available from: NTIS, Springfield, VA; PB80–190218/HBF, PB80–197429/HBF, PB80–200223/HBF, PB81–118853/HBF.
U.S. Department of Agriculture. 1984. Nutrient intakes: individuals in 48 states, years 1977–78. Nationwide Food Consumption Survey 1977–78. Report No. 1–2. Available from: Human Nutrition Information Service, U.S. Department of Agriculture, Hyattsville, MD.
U.S. Department of Agriculture. 1985a. Nationwide Food Consumption Survey, Continuing Survey of Food Intakes by Individuals, women 19–50 years and their children 1–5 years, 1 day, 1985. NFCS, CSFII Report No. 85–1. Available from: Human Nutrition Information Service, U.S. Department of Agriculture, Hyattsville, MD.
U.S. Department of Agriculture. 1985b. Nationwide Food Consumption Survey, Continuing Survey of Food Intakes by Individuals, men 19–50 years, 1 day, 1985. NFCS, CSFII Report No. 85–3. Available from: Human Nutrition Information Service, U.S. Department of Agriculture, Hyattsville, MD.
U.S. Department of Agriculture. 1988. Machine-readable data sets on composition of foods and results from food consumption surveys. Administrative Report No. 378. Survey Statistics Branch, Nutrition Monitoring Division, Human Nutrition Information Service. Available from: U.S. Department of Agriculture, Hyattsville, MD.
U.S. Department of Health and Human Services and U.S. Department of Agriculture. 1986. Nutrition monitoring in the United States: a progress report from the Joint Nutrition Monitoring Evaluation Committee. DHHS Publication No. (PHS) 86–1255. Available from: U.S. Government Printing Office, Washington, DC.