# FOREWORD

The Life Sciences Research Office (LSRO), Federation of American Societies for Experimental Biology (FASEB), provides scientific assessments of topics in the biomedical sciences. This report was written by Abby G. Ershow, Sc.D. and Kenneth P. Cantor, Ph.D., Epidemiology and Biostatistics Program, National Cancer Institute (NCI), Bethesda, Maryland, 20892. The manuscript was revised and edited in accordance with the discussions and recommendations of an ad hoc Expert Panel on Water Intake convened by LSRO. Members of the Expert Panel are identified in Chapter VIII. The manuscript was prepared for publication by LSRO under provisions of NCI Order #263-MD-810264.

The authors wish to thank Hans Plugge, M.Sc., S.M. who suggested the idea for this study; Nancy Crane, M.S., R.D., and Youngmee Park, Ph.D. (Food and Drug Administration), who reviewed the coding methodology; and David Bayliss, Ph.D. (Westat, Inc.), Thomas Fears, Ph.D (National Cancer Institute), Clifford Johnson, M.S.P.H. (National Center for Health Statistics), Linda Pickle, Ph.D. (Georgetown University), and Sholom Wacholder, Ph.D. (National Cancer Institute), who provided statistical advice. The authors also acknowledge the computer programming expertise of Karen Malley (O.R.I., Inc.), Madeleine Kennedy, Ph.D. (C.S.G., Inc.), Judy Cohen (O.R.I., Inc.), and Peter Lee (C.S.G., Inc.) which was essential to the undertaking and completion of this project.

In addition, the authors are indebted to the staff and administration of the Human Nutrition Information Service, U.S. Department of Agriculture, for their time, advice, and encouragement. Finally, the authors thank the staff of the LSRO, especially Martha A. Watt, Word Processing Systems Manager, for generating the final manuscript of this report.

Members of the ad hoc Expert Panel critically examined a draft of the report and provided suggestions and comments that were incorporated into the final report. However, the authors accept the responsibility for the contents of the report and LSRO accepts the responsibility for the production of the final report. The listing of the ad hoc Expert Panel members in Chapter VIII does not imply that they specifically endorse all statements in the report.

The final report was reviewed and approved by the LSRO Advisory Committee (which consists of representatives of each constituent Society of FASEB) under authority delegated by the Executive Committee of the Federation Board. Upon completion of these review procedures, the report was approved and transmitted to NCI by the Executive Director, FASEB.

Although this is a report of the Federation of American Societies for Experimental Biology, it does not necessarily reflect the opinion of each individual member of the FASEB constituent Societies.

(date)
Kenneth D. Fisher, Ph.D. Director Life Sciences Research Office