# SUMMARY

This report presents estimates of Total Water and Tapwater intake in the population of the continental United States. The methods used to derive the estimates are described in detail. The data used for this analysis were collected during the 1977–78 Nationwide Food Consumption Survey (NFCS) of the U.S. Department of Agriculture. The authors created a special database to quantify the total moisture and tapwater content of the foods and beverages consumed by the NFCS study subjects. All food and beverage sources, as well as drinking water, are incorporated in the estimates of Total Water intake. Estimates of Tapwater intake include drinking water and tapwater added in final home or restaurant preparation of beverages and foods. Data are presented by age group, sex, season and geographic region, and separately for pregnant women, lactating women, and breast-fed children. Average intake for all participants (n=26,081) (excluding pregnant women, lactating women, and breast-fed children) was 2,072 ± 803 g/day of Total Water, including 1,193 ± 702 g/day of Tapwater. Tapwater intake thus accounted for 55 ± 18% of Total Water consumed. For all age groups combined, drinking water contributed approximately 30% of Total Water and 54% of Tapwater; foods, 26% of Total Water and 10% of Tapwater; and other beverages, 44% of Total Water and 36% of Tapwater. Median daily Total Water intake, by age group, was 1,120 g (<1 year), 1,497 g (1–10 years), 1,874 g (11–19 years), 2,109 g (20–64 years), and 2,109 g (65+ years). Median daily Tapwater intake was 240 g (<1 year), 665 g (1–10 years), 867 g (11–19 years), 1,252 g (20–64 years), and 1,367 g (65+ years). Among adults 20–64 years old, the 5th and 95th percentiles of Total Water consumption were 1,133 g and 3,793 g. Comparable percentiles of Tapwater intake were 416 g and 2,707 g, respectively. Observation of expected trends for sex, geographical region, and season, as well as for age, reinforces the general usefulness of this approach.