# VIII AD HOC EXPERT PANEL ON WATER INTAKE

- Charlotte Cottrill, Ph.D.
  Survey Statistician
  Health Effects Research Laboratory
  U.S. Environmental Protection Agency
  Andrew W. Breidenbach Environmental
  Research Center
  26 Martin Luther King Drive
  Cincinnati, Ohio 45268
- Christine J. Lewis, Ph.D., R.D.
  Chief, Clinical Research Section
  Clinical Nutrition Branch
  Center for Food Safety and Applied
  Nutrition
  Food and Drug Administration, HFF-265
  200 C Street, SW
  Washington, DC 20204
- Kiang Liu, Ph.D.
  Professor
  Department of Community Health and
  Preventive Medicine
  Northwestern University Medical School
  Chicago, Illinois 60611
- Patricia M. Guenther, Ph.D., R.D.
  Nutrition Analyst
  Human Nutrition Information Service
  U.S. Department of Agriculture
  6505 Belcrest Road
  Hyattsville, Maryland 20782
- Clifford Johnson, M.S.P.H.
  Chief, Nutrition Statistics Branch
  Division of Health Examination Statistics
  National Center for Health Statistics
  3700 East-West Highway
  Hyattsville, Maryland 20782
- Robert L. Rizek, Ph.D.
  Director, Nutrition Monitoring Division
  Human Nutrition Information Service
  U.S. Department of Agriculture
  6506 Belcrest Road
  Hyatteville, Maryland 20782
- Mary Fran Sowers, Ph.D.
  Department of Epidemiology
  School of Public Health
  University of Michigan
  Ann Arbor, Michigan 48109