# VI DISCUSSION

## A INTRODUCTION

The very large number of subjects, the use of 3-day individually averaged values, the population-based stratified random sampling design, and the consideration of nearly every possible dietary source of Total Water and Tapwater constitute unique attributes of this study. As with all surveys, there are potential sources of bias and error that may influence how close estimates of intake are to actual intake of Total Water and Tapwater of the U.S. population during 1977–78. This discussion considers the results of this study in the context of other surveys, addresses the potential sources of bias and error, and comments on future research needs.

## B COMPARISON WITH OTHER STUDIES

Surveys of water intake have been undertaken in other countries, but most have used different methods and smaller sample sizes. The most pertinent comparisons can be made with the 1977–78 Canadian Drinking Water Consumption Study ("Canadian Study") (Canada, Environmental Health Directorate, 1981) and the 1978 Survey of Drinking Water Consumption in Great Britain ("British Study") (Hopkin and Ellis, 1980). The Canadian study examined tapwater intake from beverages, soups, and ice of 970 persons (Canada, Environmental Health Directorate, 1981). The British study focused on total water and tapwater intake from drinking water, tapwater-based beverages, and other beverages in 3,564 individuals (Hopkin and Ellis, 1980). Both studies used fixed-format diaries with sources of tapwater already listed; subjects then indicated the quantities of each consumed. The preferred between-country comparison would be of Total Water intake from all sources, because this variable is the most physiologically related to prevention of thirst and dehydration. As neither the British nor Canadian studies measured quantities of water obtained from solid foods, we cannot estimate Total Water intake in those countries. We can, however, compare mean source-specific intakes between countries using a conversion factor of 1000 g water = 1 L.

Among adults, Total Water intake from drinking water and all other beverages was very similar in Great Britain (18–54 years) and the United States (20–64 years), averaging 1.8 L/day and 1.7 L/day, respectively. To this amount, tapwater (drinking water and tapwater-based beverages) contributed a higher proportion in the United States (1.3 L/day, or 76%) than in Britain (1.1 L/day, or 61%). Canadian adults (18+ years) consumed on average 1.4 L/day from drinking water and tapwater-based beverages. Recognizing that dietary patterns differ between countries, the similarity of these various national estimates is encouraging.

For all ages combined, the mean per capita intake of tapwater from drinking water and other beverages (but not food) was 1.1 L/day in the United States and 1.0 L/day in Great Britain. In Canada the average intake of tapwater from drinking water, beverages, ice, and soup was 1.3 L/day. This higher mean population intake in the Canadian study is probably not attributable to the inclusion of ice and soup, which together only account for approximately 6% of the total, but rather to a difference in the study design. The Canadian study sample had a lower proportion of young children than did the British or American study samples.

We are not aware of any similarly designed large nationwide studies of water intake in the United States. The study of Sharrett et al. (1982) is representative of surveys carried out in well-defined locales. In Seattle, Washington, 148 families were asked about usual daily intake (in glasses or cups) of four categories of dietary items: drinking water; coffee; cold drinks; and hot drinks (including soup and tea). Questions about drinking water intake (i.e., cups or glasses of water drunk) were essentially similar in the NFCS and in the study by Sharrett et al. (1982). Results were similar in both studies for children (505 and 528 g/day, respectively), adolescents (664 and 792 g/day, respectively), and adults (674 and 612 g/day, respectively). Tapwater intake from other beverages and soups, however, was considerably higher in the Seattle Study by 2–4 fold but was closer to our estimates for Total Water intake from these sources. It is possible that subjects in the Seattle Study included not just tapwater-based but rather all cold drinks, including fluid milk, carbonated beverages, and beer, when usual daily intake of cold drinks was summed into a single response. Other methodologic differences such as the volume of a cup or glass, or not adjusting for the intrinsic water content of juices and soups (R. Sharrett, personal communication), could account for some of this discrepancy. Our results agree better with those of the British and Canadian studies, whose subjects reported each beverage item separately rather than in summated grouped categories.

## C REPRESENTATIVENESS OF THE SAMPLE

The question of nonresponse bias (i.e., whether the subjects interviewed during the NFCS are representative of those who did not participate) cannot be fully addressed with the data available to us. Persons too ill or impaired to participate in the survey or to complete the data recording procedures may be underrepresented.

Persons who did not report intake for the full 3 days were excluded from our analysis. As mentioned in Chapter III, the demographic characteristics of the subjects having complete data were very similar to those of the overall sample. We have no reason to think that the water intake of persons who completed the data collection protocol differed from those who did not. We concluded that combining the data based on three days' intake with those based on one or two days' intake could provide a less precise estimate of Total Water intake. Although combining data would increase representativeness, it would reduce precision to an unknown degree. Thus, only the data from three days' intake were reported.

Because NFCS was designed to survey characteristics of individuals in households, certain groups were not sampled. Most notable among these excluded groups were military populations living on bases, which tend to be young, healthy, and active, and institutionalized persons who, whether young or old, tend to be inactive and in poor health. The water intake of residents of Alaska, Hawaii, and Puerto Rico is also not addressed by this report.

## D SOURCES OF ERROR AND BIAS

The water content of foods was calculated by difference (i.e., subtraction) (see Chapter III). Such calculations are subject to the summed errors in the values used for fat, protein, carbohydrate, ash, and ethanol. This would be a source of random error, although probably not bias, in the estimates of Total Water and Tapwater intake. The magnitude of this error could be expected to vary among food groups.

The direction, if not always the magnitude, of certain other sources of error and bias is perhaps more easily evaluated. Study subjects inevitably make errors in reporting quantities of foods and beverages consumed, weight and height, and cups of water drunk. We have minimized the effects of these errors by deleting a small number of outliers (see Chapter IV). Both 24-hour recall and food diary methods generally underestimate varieties and quantities of foods and beverages; these underestimations are due, in part, to lapses of memory during interviews and to the inhibiting effect of writing a description of all items consumed (Swan, 1983). Unfortunately, there is no absolute standard against which to gauge the effects of these variables (Anderson, 1986). Thus, we may have underestimated the Total Water and Tapwater intake of the U.S. population because these estimates were derived directly from dietary data. Comparison with results from other studies, as discussed earlier, may be instructive. Omission of ice (and possibly drinking-fountain water, which would be particularly hard to estimate) also could lead to small underestimates of Total Water and Tapwater intake. For many individuals these probably are minor sources of water. For example, the Canadian study reported that the average intake of water from ice was less than 40 ml/day (Canada, Environmental Health Directorate, 1981). Similar minor underestimation of Total Water and Tapwater intake would result from omission of Tapwater clinging to washed foods and small quantities added to foods such as vegetables and leftovers during heating or reheating.

Deriving estimates of Tapwater intake required that we assign the source of water in each food item as either intrinsic water or indirect tapwater or as a combination of the two (see Chapter III). This process was simple and obvious for many foods and beverages (i.e., a cup of coffee, a peach, a can of cola beverage); however, in other cases, it was more difficult. For example, the exact quantities of Tapwater added during preparation of foods such as frozen concentrated orange juice or canned soup were unknown; a single figure had to be chosen for each food item and applied to the entire study population. In addition, both home and commercial preparations of many foods were grouped under a single description. In the absence of marketing data or knowledge of which type the subject consumed, only a crude estimate could be made of the proportion of homemade and commercial forms. The lack of recipes for complex mixed dishes such as soups, stews, sauces, and casseroles led to assigning the water in these items to their main ingredient (meat, vegetable, grain, etc.) rather than carefully apportioning the water among their various constituents. The magnitude of this last problem probably is not great, however, because over 70% of both Total Water and Tapwater were derived from a limited number of clearly defined sources (drinking water, coffee, tea, milk, etc.).

Partitioning the ingested water of foods and beverages into tapwater and intrinsic water may seem artificial when so many foods are purchased ready-to-eat in markets, restaurants, "fastfood" establishments and the like, whereas only a small number of items are prepared directly at home from raw ingredients. The water added to certain commercially prepared foods may be very highly processed (i.e., "polished" water) to maintain consistent taste or other characteristics in the finished product. In other cases, the added water may not undergo any special treatment. We did not attempt to estimate quantities of "commercial" water consumed by the U.S. population. However, readers may address this issue by using the Tables of Specific Dietary Sources of Total Water (Table Set I). Virtually all of the water in certain specific food groups such as beer and carbonated soft drinks is commercial water. For other food groups, the estimates of Total Water can represent the upper range of intake from these sources. More precise estimates would require proprietary information, such as recipes, that is not generally available from manufacturers and obviously would not be available from surveys such as NFCS.

We did not examine how the day of the week (especially weekend vs. weekday) influenced water intake. The British study found that on weekends alcoholic beverages (intrinsic water) tended to replace some of the tea and coffee (indirect tapwater) consumed on weekdays, but that intake of Total Water from beverages did not change appreciably (Hopkin and Ellis, 1980). The NFCS dataset had a slight proportional deficit of weekend days but no adjustment has been made for this fact. In addition, the low reported alcoholic beverage consumption seems to indicate the need for procedures to elicit more accurate information (U.S. Department of Agriculture, 1985a,b). These factors might produce a slight underestimate of Total Water intake and a slight overestimate of Tapwater intake.

We made several coding assumptions that may have contributed to an underestimate of Tapwater intake. For example, all milk used in cooking was assumed to be fresh liquid milk; thus, if any milk were reconstituted powdered, diluted evaporated, or condensed milk, the Tapwater contributed by these items may have been underestimated. Cakes made from cake mixes prepared at home were grouped with commercially prepared cakes; the Tapwater content of cakes may thus have been underestimated.

## E SPECIAL PROBLEM: INFANTS

We consider that the large sample size of this study and the relatively minor nature of the errors and biases have yielded reliable estimates of quantities of Total Water and Tapwater consumed during 1977–78 by most subgroups of the U.S. population. The main exception to this is the group of infants (children <1 year of age).

For nursing infants the estimates of the Total Water consumed are artificially low as we had no data on quantities of breast milk consumed. We did not attempt to estimate quantities of breast milk consumed. Values given for Total Water and Tapwater intake of nursing infants were derived from sources other than breast milk.

The data for both nursing and non-nursing infants receiving baby formula have additional errors stemming from the coding of the original dietary data. If the respondent did not specify the original form of the formula, the ready-to-feed code was used (U.S. Department of Agriculture, 1979). Of the 19 nursing infants using formula, 5 (26.3%) used powder, 2 (10.5%) used concentrate, and 12 (63.2%) used ready-to-feed or did not specify the original form ("nfs"). Of the 218 non-nursing infants using formula, 2 (0.9%) used powder, 51 (23.4%) used concentrate, 159 (72.9%) used ready-to-feed or did not specify the original form, and 6 (2.7%) used both concentrate and either ready-to-feed or an unspecified form. In the late 1970s, ready-to-feed formulas constituted approximately 40% of the market share, whereas over 50% of infants were fed diluted concentrate (Anderson et al., 1982). Since we assumed that all of the formula that was not specified as to form was ready-to-feed, at least some of indirect tapwater (in diluted formulas) has been assigned instead as intrinsic water (in ready-to-feed formulas). Thus, it is likely that we have underestimated the fraction of Tapwater contained in formulas at the time of feeding and have also underestimated daily intake of Tapwater in infants. Estimates of Total Water intake would not be affected by this problem because this value would reflect the total volume of formula consumed rather than the type of formula. A better estimate of Tapwater intake of nursing and non-nursing infants probably lies somewhere between the values for Tapwater intake (lower end of range) and Total Water intake (upper end of range). Readers are advised to consider using such a range of values for this age group.

## F CONCLUSIONS AND RECOMMENDATIONS

We observed the expected effects of age, sex, region, and season on both Total Water and Tapwater intake. Furthermore, median daily Total Water intakes closely paralleled various recommended baseline allowances for infants under 1 year (1.5 g/kcal or 100–160 ml/kg body weight); children 1–10 years (1.0 g/kcal or 50–100 ml/kg body weight); and adolescents 11–19 years old and adults 20+ years old (1.0 g/kcal or 30–40 ml/kg body weight) (National Research Council, 1980; Pipes, 1981; Randall, 1973). This internal and external consistency suggests that our analytical approach yielded reliable results.

The baseline recommendations for intakes of Total Water cited above are intended to foster maintenance of normal fluid and electrolyte balance and to prevent dehydration (National Research Council, 1980). Our results suggest that these "rule of thumb" allowances are in fact very close to typical (median) intakes for the healthy U.S. population. Of course, this report presents estimates of intakes rather than water requirements within the study population.

We found that distributions of Total Water intake were skewed to the right in nearly all subgroups and that many individuals clearly consumed water in excess of their theoretical "requirements.” This observation reinforces the concept that physiologic regulation of fluid balance allows considerable intake above requirements. In accord with this idea we found that only about 15% of the variance in Total Water intake of most age groups could be explained by a multivariate model including such physiologic or environmental variables as sex, age, body size, geographical region, or season of interview. Most of the variance apparently was due instead to other influences on water intake that we could not evaluate. For example, no information was collected on specific medical conditions. In addition, strenuous physical activity elevates both water requirements (National Research Council, 1980) and water intake (Canada, Environmental Health Directorate, 1981), but we lacked information on the activity level of the study subjects. Similarly, the association between cigarette smoking and high coffee consumption is well known (Hartge et al., 1983), but we did not know which study subjects smoked. We therefore cannot conclude that the most active subjects or the smokers also consumed the most water, nor can the tables necessarily be used to specify quantities of water to be consumed during heavy exercise. More information is needed on the relationship between water intake and habitual behaviors or specific illnesses.

The 1977–78 Nationwide Food Consumption Survey was not originally designed to study water intake. Moreover, information was not collected about factors that might affect estimates of exposure to waterborne contaminants, such as water source; use of ice; place where water was consumed; and type of household plumbing. Questions of this nature are typical of studies whose main focus is water and would be a most useful addition to future surveys.

Finally, we observed marked age-group differences in quantities and sources of water consumed in this cross-sectional study. Longitudinal studies are needed to evaluate the changes in consumption patterns occurring in a defined cohort of individuals over an extended time period.

Many dietary changes have taken place in the United States in the time since the data used for this analysis were gathered (U.S. Department of Agriculture, 1985a,b). More meals are prepared and eaten outside the home; powdered infant formulas are more widely available; soft drink consumption has increased; and use of bottled drinking water has become more popular. For example, between 1977 and 1985 the average intake of low-calorie carbonated soft drinks (which includes sparkling waters) reportedly increased 2-fold for women and 5-fold for men aged 19–50 years (U.S. Department of Agriculture, 1985a,b). As interest in exposure to substances in the nation's food and water supply continues, shifts in the relative contributions of sources of Tapwater and Intrinsic Water (including "commercial" water) will be best evaluated by comparison with estimates of Total Water intake.