# V RESULTS

## A OVERVIEW

This section summarizes major findings, paying particular attention to age trends as well as effects of sex, region, and season. The figures accompanying this section are based on the entire study population, excluding pregnant women, lactating women, and breast-fed children. Detailed information on all groups (Fine Age groupings; Broad Age groupings; and pregnant women, lactating women, and breast-fed children) can be found in Table Sets A through L.

### A TOTAL WATER INTAKE (g/day)

Set A. Table 1 Total Water Intake (g/day) by Broad Age Category and Sex (All Regions, All Seasons)^§◆^

Sex | Age (yr) | Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Sex | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Both Sexes | < 1 | 403 | 444.3 | 1148 | 332 | 17 | 510 | 631 | 759 | 920 | 1120 | 1339 | 1597 | 1727 | 2060
| 1–10 | 5605 | 6354.1 | 1559 | 507 | 7 | 617 | 838 | 970 | 1210 | 1497 | 1843 | 2236 | 2507 | 3013
| 11–19 | 5801 | 6824.9 | 1989 | 719 | 9 | 717 | 1025 | 1196 | 1489 | 1874 | 2369 | 2908 | 3336 | 4251
| 20–64 | 11731 | 21744.9 | 2243 | 839 | 8 | 821 | 1133 | 1324 | 1665 | 2109 | 2663 | 3318 | 3793 | 5081
| 65+ | 2541 | 4142.0 | 2199 | 728 | 14 | 860 | 1196 | 1352 | 1700 | 2109 | 2616 | 3132 | 3482 | 4370
| All | 26081 | 39510.2 | 2072 | 803 | 5 | 728 | 1012 | 1188 | 1511 | 1950 | 2485 | 3098 | 3550 | 4655
Males | < 1 | 200 | 219.4 | 1152 | 324 | 23 | * | 642 | 769 | 922 | 1127 | 1344 | 1531 | 1731 | *
| 1–10 | 2854 | 3223.8 | 1594 | 517 | 10 | 628 | 848 | 987 | 1235 | 1531 | 1895 | 2284 | 2538 | 3093
| 11–19 | 2844 | 3363.2 | 2210 | 769 | 14 | 821 | 1170 | 1359 | 1673 | 2095 | 2626 | 3249 | 3634 | 4534
| 20–64 | 5023 | 9168.1 | 2515 | 916 | 13 | 902 | 1310 | 1514 | 1889 | 2374 | 2976 | 3700 | 4244 | 5529
| 65+ | 967 | 1698.1 | 2407 | 778 | 25 | 1032 | 1329 | 1528 | 1886 | 2305 | 2832 | 3390 | 3799 | 4844
| All | 11888 | 17672.6 | 2261 | 888 | 8 | 769 | 1074 | 1274 | 1641 | 2132 | 2719 | 3414 | 3903 | 5200
Females | < 1 | 203 | 225.0 | 1144 | 341 | 24 | * | 631 | 759 | 918 | 1118 | 1319 | 1604 | 1704 | *
| 1–10 | 2751 | 3130.2 | 1523 | 493 | 9 | 609 | 827 | 957 | 1176 | 1462 | 1800 | 2181 | 2437 | 2979
| 11–19 | 2957 | 3461.7 | 1773 | 594 | 11 | 633 | 947 | 1100 | 1367 | 1696 | 2104 | 2542 | 2812 | 3483
| 20–64 | 6708 | 12576.8 | 2045 | 716 | 9 | 789 | 1068 | 1238 | 1547 | 1952 | 2421 | 2970 | 3338 | 4216
| 65+ | 1574 | 2443.9 | 2055 | 653 | 16 | 841 | 1122 | 1288 | 1597 | 1985 | 2425 | 2925 | 3257 | 3854
| All | 14193 | 21837.6 | 1919 | 691 | 6 | 697 | 972 | 1136 | 1433 | 1823 | 2299 | 2816 | 3166 | 4027

§ Does not include pregnant women, lactating women, or breast-fed children.

◆ Individual values may not add to totals due to rounding.

* Value not reported due to insufficient number of observations.

Set A. Table 2 Total Water Intake (g/day) by Fine Age Category and Sex (All Regions, All Seasons)^§◆^

Sex | Age (yr) | Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Sex | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Both Sexes | < 0.5 | 182 | 201.2 | 1014 | 294 | 22 | * | 587 | 652 | 842 | 974 | 1168 | 1344 | 1516 | *
| 0.5–0.9 | 221 | 243.2 | 1258 | 322 | 22 | * | 769 | 854 | 1038 | 1250 | 1463 | 1629 | 1766 | *
| 1– 3 | 1498 | 1687.7 | 1356 | 450 | 12 | 552 | 731 | 842 | 1041 | 1299 | 1601 | 1915 | 2220 | 2703
| 4– 6 | 1702 | 1923.9 | 1520 | 482 | 12 | 613 | 835 | 967 | 1197 | 1464 | 1796 | 2144 | 2374 | 2913
| 7–10 | 2405 | 2742.4 | 1711 | 508 | 10 | 774 | 990 | 1119 | 1355 | 1652 | 1990 | 2392 | 2609 | 3209
| 11–14 | 2803 | 3146.9 | 1918 | 651 | 12 | 702 | 1041 | 1191 | 1469 | 1822 | 2278 | 2738 | 3140 | 3876
| 15–19 | 2998 | 3677.9 | 2049 | 768 | 14 | 729 | 1013 | 1206 | 1508 | 1933 | 2454 | 3029 | 3469 | 4500
| 20–44 | 7171 | 13444.5 | 2171 | 839 | 10 | 788 | 1083 | 1266 | 1597 | 2032 | 2589 | 3239 | 3702 | 5054
| 45–64 | 4560 | 8300.4 | 2359 | 826 | 12 | 948 | 1256 | 1439 | 1805 | 2241 | 2771 | 3436 | 3921 | 5129
| 65–74 | 1663 | 2740.2 | 2249 | 739 | 18 | 902 | 1216 | 1388 | 1738 | 2151 | 2680 | 3237 | 3580 | 4414
| 75+ | 878 | 1401.8 | 2103 | 697 | 24 | 739 | 1175 | 1305 | 1633 | 2040 | 2485 | 2940 | 3267 | 4074
| All | 26081 | 39510.2 | 2072 | 803 | 5 | 728 | 1012 | 1188 | 1511 | 1950 | 2485 | 3098 | 3550 | 4655
Males | < 0.5 | 87 | 96.4 | 992 | 286 | 31 | * | 536 | 652 | 865 | 962 | 1112 | 1355 | 1505 | *
| 0.5–0.9 | 113 | 122.9 | 1277 | 296 | 28 | * | 801 | 896 | 1094 | 1256 | 1471 | 1629 | 1766 | *
| 1– 3 | 775 | 879.6 | 1409 | 462 | 17 | 596 | 778 | 867 | 1087 | 1348 | 1666 | 1995 | 2280 | 2812
| 4– 6 | 883 | 991.4 | 1551 | 484 | 16 | 610 | 836 | 975 | 1225 | 1498 | 1843 | 2180 | 2399 | 2902
| 7–10 | 1196 | 1352.9 | 1746 | 530 | 15 | 733 | 990 | 1130 | 1383 | 1686 | 2061 | 2456 | 2689 | 3233
| 11–14 | 1395 | 1571.8 | 2054 | 683 | 18 | 790 | 1133 | 1303 | 1585 | 1948 | 2403 | 2977 | 3410 | 4188
| 15–19 | 1449 | 1791.4 | 2348 | 812 | 21 | 847 | 1240 | 1433 | 1797 | 2230 | 2782 | 3412 | 3819 | 4913
| 20–44 | 3146 | 5702.7 | 2470 | 927 | 17 | 881 | 1242 | 1473 | 1821 | 2315 | 2950 | 3655 | 4236 | 5553
| 45–64 | 1877 | 3465.4 | 2587 | 892 | 21 | 1033 | 1389 | 1601 | 1985 | 2444 | 3021 | 3756 | 4264 | 5373
| 65–74 | 656 | 1172.3 | 2439 | 788 | 31 | 932 | 1355 | 1563 | 1922 | 2340 | 2874 | 3439 | 3839 | 4844
| 75+ | 311 | 525.8 | 2335 | 753 | 43 | * | 1317 | 1427 | 1780 | 2272 | 2756 | 3209 | 3622 | *
| All | 11888 | 17672.6 | 2261 | 888 | 8 | 769 | 1074 | 1274 | 1641 | 2132 | 2719 | 3414 | 3903 | 5200
Females | < 0.5 | 95 | 104.7 | 1035 | 300 | 31 | * | 624 | 668 | 825 | 1014 | 1190 | 1321 | 1643 | *
| 0.5–0.9 | 108 | 120.2 | 1238 | 348 | 33 | * | 728 | 785 | 995 | 1209 | 1462 | 1651 | 1721 | *
| 1– 3 | 723 | 808.2 | 1300 | 430 | 16 | 536 | 708 | 799 | 1015 | 1236 | 1526 | 1844 | 2071 | 2645
| 4– 6 | 819 | 932.5 | 1488 | 477 | 17 | 643 | 834 | 959 | 1171 | 1408 | 1750 | 2086 | 2349 | 2960
| 7–10 | 1209 | 1389.5 | 1676 | 483 | 14 | 813 | 991 | 1107 | 1344 | 1622 | 1933 | 2336 | 2567 | 3070
| 11–14 | 1408 | 1575.1 | 1782 | 586 | 16 | 649 | 982 | 1118 | 1377 | 1706 | 2101 | 2541 | 2810 | 3383
| 15–19 | 1549 | 1886.5 | 1766 | 600 | 15 | 622 | 914 | 1083 | 1359 | 1689 | 2107 | 2544 | 2820 | 3513
| 20–44 | 4025 | 7741.7 | 1951 | 689 | 11 | 735 | 1006 | 1182 | 1479 | 1844 | 2321 | 2843 | 3204 | 4069
| 45–64 | 2683 | 4835.1 | 2195 | 733 | 14 | 920 | 1171 | 1367 | 1700 | 2099 | 2569 | 3110 | 3503 | 4470
| 65–74 | 1007 | 1567.9 | 2107 | 665 | 21 | 902 | 1139 | 1310 | 1623 | 2023 | 2517 | 2997 | 3334 | 3858
| 75+ | 567 | 876.0 | 1963 | 621 | 26 | 599 | 1103 | 1246 | 1552 | 1918 | 2328 | 2746 | 3072 | 3723
| All | 14193 | 21837.6 | 1919 | 691 | 6 | 697 | 972 | 1136 | 1433 | 1823 | 2299 | 2816 | 3166 | 4027

§ Does not include pregnant women, lactating women, or breast-fed children.

◆ Individual values may not add to totals due to rounding.

* Value not reported due to insufficient number of observations.

Set A. Table 3 Total Water Intake (g/day) of Pregnant Women, Lactating Women, and Breast-fed Children (All Regions, All Seasons)

| Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
| Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 5 | 10 | 25 | 50 | 75 | 90 | 95
Pregnant women | 188 | 327.5 | 2076 | 743 | 54 | 1085 | 1236 | 1553 | 1928 | 2444 | 3028 | 3475
Lactating women | 77 | 151.2 | 2242 | 658 | 75 | 1185 | 1434 | 1833 | 2164 | 2658 | 3169 | 3353
Breast-fed children^§^
Both sexes
All ages | 100 | 121.0 | 402 | 352 | 35 | 0 | 0 | 69 | 315 | 633 | 902 | 1023
< 0.5 yr | 62 | 74.4 | 316 | 358 | 45 | * | 0 | 0 | 189 | 582 | 902 | *
≥ 0.5 yr | 38 | 46.6 | 539 | 300 | 49 | * | 181 | 300 | 499 | 803 | 1003 | *
Males
All ages | 42 | 49.4 | 377 | 353 | 54 | * | 0 | 63 | 208 | 670 | 872 | *
< 0.5 yr | 28 | 34.0 | 311 | 357 | 67 | * | * | 0 | 160 | 601 | * | *
≥ 0.5 yr | 14 | 15.5 | * | * | * | * | * | 182 | 580 | 803 | * | *
Females
All ages | 58 | 71.6 | 419 | 353 | 46 | * | 0 | 148 | 337 | 622 | 1003 | *
< 0.5 yr | 34 | 40.5 | 321 | 362 | 62 | * | * | 0 | 240 | 576 | * | *
≥ 0.5 yr | 24 | 31.1 | * | * | * | * | * | 315 | 487 | 766 | * | *

§ Total Water intake of breast-fed children does not include the contribution of breast milk

* Value not reported due to insufficient number of observations.[brr] 0 Less than 0.5 g/day.

Set A. Table 4 Total Water Intake (g/day) of Both Sexes by Broad Age Category and Geographic Region (All Seasons) ^§◆^

Region | Age (yr) | Mumber of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Region | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Northeast | < 1 | 84 | 95.7 | 1085 | 257 | 28 | * | 624 | 746 | 893 | 1094 | 1243 | 1422 | 1510 | *
| 1–10 | 1323 | 1519.2 | 1444 | 456 | 13 | 607 | 801 | 899 | 1133 | 1380 | 1697 | 1984 | 2275 | 2979
| 11–19 | 1324 | 1565.0 | 1830 | 657 | 18 | 633 | 979 | 1142 | 1395 | 1734 | 2160 | 2631 | 3011 | 3972
| 20–64 | 2883 | 5548.0 | 2048 | 713 | 13 | 800 | 1100 | 1252 | 1549 | 1959 | 2414 | 2923 | 3288 | 4261
| 65+ | 584 | 959.4 | 2020 | 676 | 28 | 860 | 1107 | 1254 | 1577 | 1954 | 2395 | 2828 | 3069 | 3894
| All | 6198 | 9687.3 | 1906 | 702 | 9 | 707 | 972 | 1132 | 1420 | 1799 | 2275 | 2784 | 3136 | 4103
Midwest | < 1 | 101 | 114.5 | 1191 | 319 | 32 | * | 769 | 798 | 935 | 1168 | 1413 | 1614 | 1704 | *
| 1–10 | 1505 | 1700.8 | 1597 | 494 | 13 | 697 | 861 | 1017 | 1254 | 1546 | 1865 | 2262 | 2523 | 2983
| 11–19 | 1611 | 1908.0 | 2008 | 719 | 18 | 763 | 1036 | 1207 | 1512 | 1915 | 2390 | 2892 | 3252 | 4484
| 20–64 | 2972 | 5593.4 | 2278 | 807 | 15 | 847 | 1187 | 1395 | 1718 | 2172 | 2705 | 3261 | 3751 | 4775
| 65+ | 604 | 1037.5 | 2253 | 699 | 28 | 932 | 1252 | 1439 | 1761 | 2179 | 2667 | 3237 | 3462 | 4421
| All | 6793 | 10354.2 | 2102 | 780 | 9 | 760 | 1048 | 1232 | 1562 | 1986 | 2524 | 3087 | 3499 | 4509
South | < 1 | 150 | 146.3 | 1144 | 365 | 30 | * | 547 | 723 | 873 | 1109 | 1366 | 1616 | 1819 | *
| 1–10 | 1928 | 2006.8 | 1575 | 523 | 12 | 584 | 847 | 974 | 1219 | 1507 | 1874 | 2296 | 2550 | 2998
| 11–19 | 1982 | 2154.1 | 2039 | 712 | 16 | 746 | 1097 | 1244 | 1550 | 1933 | 2408 | 2950 | 3382 | 4251
| 20–64 | 3980 | 6642.8 | 2277 | 872 | 14 | 794 | 1130 | 1313 | 1678 | 2145 | 2702 | 3408 | 3874 | 5183
| 65+ | 970 | 1448.1 | 2209 | 758 | 24 | 791 | 1184 | 1352 | 1682 | 2093 | 2655 | 3209 | 3577 | 4414
| All | 9010 | 12398.1 | 2101 | 826 | 9 | 718 | 1006 | 1196 | 1522 | 1977 | 2519 | 3165 | 3610 | 4830
West | < 1 | 68 | 87.7 | 1166 | 359 | 44 | * | 631 | 748 | 939 | 1127 | 1321 | 1727 | 1866 | *
| 1–10 | 849 | 1127.2 | 1629 | 536 | 18 | 650 | 864 | 986 | 1250 | 1554 | 1972 | 2329 | 2580 | 3233
| 11–19 | 884 | 1197.8 | 2073 | 779 | 26 | 693 | 1009 | 1187 | 1509 | 1954 | 2504 | 3183 | 3594 | 4258
| 20–64 | 1896 | 3960.7 | 2409 | 934 | 21 | 864 | 1154 | 1374 | 1766 | 2246 | 2907 | 3645 | 4151 | 5540
| 65+ | 383 | 697.0 | 2347 | 727 | 37 | 1088 | 1264 | 1467 | 1844 | 2268 | 2767 | 3299 | 3706 | 4159
| All | 4080 | 7070.4 | 2206 | 886 | 14 | 748 | 1022 | 1216 | 1575 | 2070 | 2675 | 3368 | 3852 | 5168
All Regions | All | 26081 | 39510.2 | 2072 | 803 | 2 | 728 | 1012 | 1188 | 1511 | 1950 | 2485 | 3098 | 3550 | 4655

§ Does not include pregnant women, lactating women, or breast-fed children.

◆ Individual values may not add to totals due to rounding.

* Value not reported due to insufficient number of observations.

Set A. Table 5 Total Water Intake (g/day) of Males by Broad Age Category and Geographic Region (All Seasons) ^§◆^

Region | Age (yr) | Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Region | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Northeast | < 1 | 36 | 38.9 | 1147 | 217 | 36 | * | * | 867 | 990 | 1203 | 1296 | 1422 | * | *
| 1–10 | 674 | 765.4 | 1456 | 446 | 17 | 551 | 812 | 912 | 1142 | 1407 | 1713 | 2013 | 2286 | 2742
| 11–19 | 660 | 772.9 | 2014 | 721 | 28 | 732 | 1066 | 1273 | 1518 | 1909 | 2348 | 2908 | 3453 | 4129
| 20–64 | 1226 | 2310.2 | 2260 | 789 | 23 | 820 | 1189 | 1383 | 1705 | 2179 | 2662 | 3201 | 3710 | 5027
| 65+ | 217 | 375.2 | 2225 | 755 | 51 | * | 1238 | 1407 | 1746 | 2163 | 2581 | 2992 | 3281 | *
| All | 2813 | 4262.6 | 2058 | 785 | 15 | 746 | 1010 | 1196 | 1512 | 1967 | 2478 | 3007 | 3487 | 4670
Midwest | < 1 | 53 | 59.5 | 1180 | 307 | 42 | * | * | 856 | 925 | 1163 | 1355 | 1571 | * | *
| 1–10 | 796 | 903.3 | 1634 | 520 | 18 | 697 | 849 | 1017 | 1283 | 1581 | 1933 | 2309 | 2569 | 3052
| 11–19 | 785 | 942.5 | 2243 | 760 | 27 | 847 | 1177 | 1402 | 1738 | 2137 | 2645 | 3158 | 3640 | 4742
| 20–64 | 1325 | 2442.6 | 2535 | 866 | 24 | 1022 | 1413 | 1595 | 1935 | 2421 | 2959 | 3640 | 4169 | 5283
| 65+ | 238 | 440.3 | 2409 | 757 | 49 | * | 1427 | 1563 | 1867 | 2272 | 2852 | 3412 | 3727 | *
| All | 3197 | 4788.2 | 2279 | 854 | 15 | 781 | 1130 | 1326 | 1695 | 2161 | 2727 | 3335 | 3864 | 4948
South | < 1 | 74 | 72.3 | 1129 | 369 | 43 | * | 528 | 624 | 869 | 1081 | 1372 | 1626 | 1701 | *
| 1–10 | 974 | 1005.9 | 1620 | 528 | 17 | 621 | 897 | 1027 | 1244 | 1558 | 1918 | 2338 | 2570 | 3199
| 11–19 | 969 | 1071.3 | 2254 | 756 | 24 | 979 | 1240 | 1403 | 1710 | 2147 | 2670 | 3254 | 3631 | 4422
| 20–64 | 1645 | 2707.0 | 2603 | 974 | 24 | 971 | 1313 | 1530 | 1922 | 2422 | 3146 | 3845 | 4464 | 5616
| 65+ | 360 | 577.4 | 2455 | 803 | 42 | * | 1329 | 1535 | 1925 | 2379 | 2900 | 3516 | 3839 | *
| All | 4022 | 5433.9 | 2317 | 927 | 15 | 753 | 1086 | 1280 | 1667 | 2172 | 2804 | 3538 | 4025 | 5395
West | < 1 | 37 | 48.6 | 1155 | 349 | 57 | * | * | 721 | 953 | 1095 | 1331 | 1727 | * | *
| 1–10 | 410 | 549.2 | 1672 | 551 | 27 | 653 | 866 | 970 | 1323 | 1587 | 2025 | 2420 | 2611 | 3275
| 11–19 | 430 | 576.5 | 2338 | 820 | 40 | 881 | 1196 | 1389 | 1744 | 2216 | 2806 | 3474 | 3788 | 4618
| 20–64 | 827 | 1708.3 | 2690 | 976 | 34 | 949 | 1387 | 1610 | 1998 | 2513 | 3223 | 3973 | 4416 | 5708
| 65+ | 152 | 305.1 | 2536 | 753 | 61 | * | 1302 | 1583 | 2113 | 2468 | 2978 | 3490 | 3982 | *
| All | 1856 | 3187.7 | 2413 | 950 | 22 | 804 | 1113 | 1338 | 1750 | 2259 | 2937 | 3709 | 4159 | 5495
All Regions | All | 11888 | 17672.6 | 2261 | 888 | 8 | 769 | 1074 | 1274 | 1641 | 2132 | 2719 | 3414 | 3903 | 5200

§ Does not include breast-fed children.

◆ Individual values may not add to totals due to rounding.

* Value not reported due to insufficient number of observations.

Set A. Table 6 Total Water Intake (g/day) of Females by Broad Age Category and Geographic Region (All Seasons) ^§◆^

Region | Age (yr) | Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Region | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Northeast | < 1 | 48 | 56.8 | 1043 | 275 | 40 | * | * | 629 | 851 | 1068 | 1191 | 1470 | * | *
| 1–10 | 649 | 753.8 | 1432 | 465 | 18 | 627 | 789 | 889 | 1121 | 1355 | 1674 | 1955 | 2237 | 3099
| 11–19 | 664 | 792.1 | 1650 | 529 | 21 | 529 | 914 | 1048 | 1326 | 1594 | 1926 | 2289 | 2565 | 3177
| 20–64 | 1657 | 3237.9 | 1896 | 610 | 15 | 796 | 1067 | 1198 | 1475 | 1821 | 2218 | 2668 | 3020 | 3789
| 65+ | 367 | 584.2 | 1889 | 585 | 31 | * | 1058 | 1215 | 1487 | 1808 | 2239 | 2674 | 2883 | *
| All | 3385 | 5424.8 | 1786 | 604 | 10 | 668 | 957 | 1103 | 1370 | 1716 | 2117 | 2557 | 2882 | 3594
Midwest | < 1 | 48 | 55.0 | 1203 | 334 | 48 | * | * | 782 | 969 | 1198 | 1493 | 1643 | * | *
| 1–10 | 709 | 797.5 | 1554 | 459 | 17 | 712 | 884 | 1015 | 1239 | 1509 | 1806 | 2164 | 2396 | 2854
| 11–19 | 826 | 965.5 | 1779 | 594 | 21 | 675 | 927 | 1095 | 1378 | 1722 | 2110 | 2515 | 2777 | 3513
| 20–64 | 1647 | 3150.8 | 2078 | 696 | 17 | 793 | 1101 | 1287 | 1602 | 1979 | 2495 | 2968 | 3324 | 4172
| 65+ | 366 | 597.2 | 2138 | 629 | 33 | * | 1183 | 1353 | 1718 | 2067 | 2497 | 3000 | 3307 | *
| All | 3596 | 5566.0 | 1949 | 675 | 11 | 731 | 1008 | 1176 | 1473 | 1843 | 2353 | 2828 | 3150 | 4007
South | < 1 | 76 | 74.0 | 1158 | 364 | 42 | * | 695 | 759 | 918 | 1124 | 1324 | 1560 | 1920 | *
| 1–10 | 954 | 1000.9 | 1529 | 514 | 17 | 555 | 826 | 943 | 1171 | 1467 | 1823 | 2242 | 2464 | 2993
| 11–19 | 1013 | 1082.8 | 1827 | 593 | 19 | 652 | 1003 | 1157 | 1403 | 1759 | 2183 | 2609 | 2833 | 3425
| 20–64 | 2335 | 3935.7 | 2053 | 713 | 15 | 731 | 1044 | 1230 | 1557 | 1982 | 2437 | 2967 | 3330 | 4231
| 65+ | 610 | 870.7 | 2045 | 680 | 28 | 812 | 1112 | 1281 | 1566 | 1946 | 2440 | 2950 | 3287 | 4089
| All | 4988 | 6964.1 | 1932 | 693 | 10 | 692 | 961 | 1141 | 1437 | 1852 | 2326 | 2833 | 3172 | 3984
West | < 1 | 31 | 39.2 | 1179 | 375 | 67 | * | * | * | 939 | 1127 | 1321 | * | * | *
| 1–10 | 439 | 578.0 | 1588 | 518 | 25 | 608 | 844 | 993 | 1198 | 1508 | 1913 | 2261 | 2545 | 2988
| 11–19 | 454 | 621.3 | 1828 | 649 | 30 | 673 | 894 | 1069 | 1371 | 1737 | 2192 | 2650 | 2967 | 3716
| 20–64 | 1069 | 2252.5 | 2196 | 840 | 26 | 821 | 1066 | 1249 | 1606 | 2070 | 2641 | 3299 | 3685 | 5168
| 65+ | 231 | 391.9 | 2199 | 672 | 44 | * | 1224 | 1389 | 1751 | 2129 | 2592 | 3091 | 3401 | *
| All | 2224 | 3882.9 | 2037 | 791 | 17 | 696 | 982 | 1140 | 1484 | 1916 | 2442 | 3071 | 3510 | 4503
All Regions | All | 14193 | 21837.6 | 1919 | 691 | 6 | 697 | 972 | 1136 | 1433 | 1823 | 2299 | 2816 | 3166 | 4027

§ Does not include pregnant women, lactating women, or breast-fed children.

◆ Individual values may not add to totals due to rounding.

* Value not reported due to insufficient number of observations.

Set A. Table 7 Total Water Intake (g/day) of Both Sexes by Broad Age Category and Season (All Regions) ^§◆^

Season | Age (yr) | Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Season | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Spring | < 1 | 63 | 78.9 | 1124 | 361 | 45 | * | * | 723 | 866 | 1079 | 1318 | 1604 | * | *
| 1–10 | 1117 | 1511.9 | 1544 | 486 | 15 | 610 | 817 | 964 | 1219 | 1500 | 1814 | 2202 | 2425 | 2910
| 11–19 | 1332 | 1760.4 | 2030 | 732 | 20 | 792 | 1064 | 1235 | 1517 | 1926 | 2390 | 2962 | 3449 | 4345
| 20–64 | 3997 | 5258.9 | 2250 | 841 | 13 | 820 | 1147 | 1330 | 1675 | 2105 | 2665 | 3317 | 3802 | 5064
| 65+ | 770 | 996.5 | 2239 | 709 | 26 | 912 | 1238 | 1401 | 1745 | 2157 | 2670 | 3136 | 3439 | 4083
| All | 7279 | 9606.6 | 2088 | 804 | 9 | 735 | 1028 | 1211 | 1528 | 1964 | 2505 | 3130 | 3565 | 4673
Summer | < 1 | 107 | 130.1 | 1176 | 327 | 32 | * | 676 | 782 | 948 | 1163 | 1405 | 1531 | 1701 | *
| 1–10 | 1321 | 1568.1 | 1600 | 513 | 14 | 652 | 884 | 1019 | 1236 | 1530 | 1903 | 2284 | 2538 | 3261
| 11–19 | 1356 | 1672.0 | 2061 | 774 | 21 | 710 | 1043 | 1217 | 1515 | 1935 | 2456 | 3090 | 3513 | 4383
| 20–64 | 2327 | 5534.3 | 2342 | 903 | 19 | 868 | 1178 | 1369 | 1722 | 2193 | 2772 | 3510 | 4069 | 5465
| 65+ | 513 | 1025.1 | 2359 | 819 | 36 | 952 | 1247 | 1422 | 1762 | 2262 | 2813 | 3418 | 3866 | 4706
| All | 5624 | 9929.6 | 2164 | 868 | 12 | 788 | 1049 | 1224 | 1547 | 2031 | 2588 | 3288 | 3772 | 5144
Fall | < 1 | 108 | 109.7 | 1142 | 323 | 31 | * | 547 | 629 | 947 | 1126 | 1344 | 1560 | 1674 | *
| 1–10 | 1619 | 1648.4 | 1571 | 517 | 13 | 609 | 850 | 988 | 1205 | 1496 | 1857 | 2283 | 2558 | 2983
| 11–19 | 1584 | 1717.0 | 1934 | 684 | 17 | 700 | 1006 | 1165 | 1447 | 1840 | 2348 | 2746 | 3140 | 3952
| 20–64 | 2692 | 5444.0 | 2185 | 808 | 16 | 864 | 1125 | 1303 | 1620 | 2045 | 2596 | 3218 | 3685 | 5116
| 65+ | 632 | 1073.3 | 2137 | 708 | 28 | 841 | 1093 | 1309 | 1684 | 2054 | 2485 | 3073 | 3482 | 4031
| All | 6635 | 9992.4 | 2024 | 771 | 9 | 739 | 1007 | 1164 | 1476 | 1909 | 2421 | 3007 | 3458 | 4441
Winter | < 1 | 125 | 125.7 | 1139 | 330 | 30 | * | 712 | 790 | 888 | 1114 | 1290 | 1629 | 1766 | *
| 1–10 | 1548 | 1625.7 | 1521 | 506 | 13 | 597 | 784 | 915 | 1171 | 1473 | 1800 | 2195 | 2401 | 3012
| 11–19 | 1529 | 1675.6 | 1928 | 674 | 17 | 680 | 979 | 1171 | 1488 | 1829 | 2266 | 2794 | 3152 | 3999
| 20–64 | 2715 | 5507.7 | 2194 | 789 | 15 | 731 | 1093 | 1305 | 1658 | 2090 | 2627 | 3177 | 3616 | 4547
| 65+ | 626 | 1047.1 | 2070 | 635 | 25 | 804 | 1176 | 1304 | 1617 | 2040 | 2481 | 2928 | 3196 | 3723
| All | 6543 | 9981.8 | 2014 | 757 | 9 | 670 | 962 | 1155 | 1493 | 1901 | 2425 | 2989 | 3376 | 4318
All Seasons | All | 26081 | 39510.2 | 2072 | 803 | 5 | 728 | 1012 | 1188 | 1511 | 1950 | 2485 | 3098 | 3550 | 4655

§ Does not include pregnant women, lactating women, or breast-fed children.

◆ Individual values may not add to totals due to rounding.

* Value not reported due to insufficient number of observations.

Set A. Table 8 Total Water Intake (g/day) of Males by Broad Age Category and Season (All Regions) ^§◆^

Season | Age (yr) | Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Season | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Spring | < 1 | 30 | 39.3 | 1138 | 318 | 58 | * | * | * | 920 | 1081 | 1326 | * | * | *
| 1–10 | 581 | 795.7 | 1578 | 489 | 20 | 613 | 817 | 985 | 1243 | 1541 | 1864 | 2209 | 2452 | 2848
| 11–19 | 657 | 883.8 | 2288 | 766 | 30 | 957 | 1241 | 1409 | 1751 | 2178 | 2711 | 3334 | 3732 | 4500
| 20–64 | 1858 | 2425.7 | 2538 | 919 | 21 | 1016 | 1348 | 1551 | 1885 | 2390 | 3032 | 3696 | 4221 | 5495
| 65+ | 326 | 421.0 | 2453 | 761 | 42 | * | 1359 | 1578 | 1933 | 2379 | 2921 | 3399 | 3700 | *
| All | 3452 | 4565.5 | 2302 | 890 | 15 | 779 | 1104 | 1326 | 1678 | 2157 | 2791 | 3444 | 3896 | 5151
Sumner | < 1 | 63 | 71.6 | 1172 | 321 | 40 | * | * | 746 | 972 | 1168 | 1414 | 1516 | * | *
| 1–10 | 655 | 779.4 | 1627 | 534 | 21 | 652 | 884 | 1028 | 1253 | 1545 | 1933 | 2317 | 2579 | 3275
| 11–19 | 642 | 800.2 | 2309 | 836 | 33 | 880 | 1252 | 1389 | 1708 | 2165 | 2789 | 3462 | 3803 | 4913
| 20–64 | 952 | 2284.1 | 2653 | 1021 | 33 | 905 | 1316 | 1519 | 1979 | 2449 | 3146 | 4014 | 4746 | 5708
| 65+ | 185 | 404.2 | 2657 | 898 | 66 | * | 1408 | 1666 | 2065 | 2577 | 3070 | 3860 | 4269 | *
| All | 2497 | 4339.5 | 2381 | 989 | 20 | 812 | 1112 | 1288 | 1681 | 2223 | 2870 | 3671 | 4291 | 5554
Fall | < 1 | 47 | 50.4 | 1126 | 310 | 45 | * | * | 769 | 926 | 1094 | 1342 | 1512 | * | *
| 1–10 | 840 | 836.1 | 1607 | 519 | 18 | 693 | 871 | 1017 | 1242 | 1532 | 1896 | 2331 | 2568 | 3052
| 11–19 | 776 | 833.4 | 2134 | 740 | 27 | 790 | 1137 | 1287 | 1600 | 2050 | 2546 | 3058 | 3421 | 4745
| 20–64 | 1031 | 2085.3 | 2434 | 872 | 27 | 949 | 1276 | 1455 | 1827 | 2304 | 2881 | 3616 | 4055 | 5242
| 65+ | 219 | 424.1 | 2304 | 743 | 50 | * | 1335 | 1506 | 1839 | 2230 | 2605 | 3390 | 3797 | *
| All | 2913 | 4229.3 | 2183 | 839 | 16 | 778 | 1066 | 1247 | 1592 | 2063 | 2616 | 3263 | 3780 | 4890
Winter | < 1 | 60 | 58.1 | 1158 | 349 | 45 | * | * | 799 | 896 | 1102 | 1352 | 1731 | * | *
| 1–10 | 778 | 812.6 | 1564 | 525 | 19 | 536 | 817 | 929 | 1212 | 1513 | 1848 | 2244 | 2468 | 3185
| 11–19 | 769 | 845.8 | 2110 | 711 | 26 | 729 | 1053 | 1338 | 1650 | 2012 | 2479 | 3029 | 3412 | 4332
| 20–64 | 1182 | 2373.0 | 2429 | 821 | 24 | 855 | 1292 | 1531 | 1860 | 2327 | 2868 | 3490 | 4016 | 4922
| 65+ | 237 | 448.8 | 2235 | 638 | 41 | * | 1218 | 1421 | 1768 | 2211 | 2661 | 3046 | 3251 | *
| All | 3026 | 4538.3 | 2179 | 807 | 15 | 728 | 1029 | 1239 | 1630 | 2080 | 2627 | 3190 | 3635 | 4509
All Seasons | All | 11888 | 17672.6 | 2261 | 888 | 8 | 769 | 1074 | 1274 | 1641 | 2132 | 2719 | 3414 | 3903 | 5200

§ Does not include breast-fed children.

◆ Individual values may not add to totals due to rounding.

* Value not reported due to insufficient number of observations.

Set A. Table 9 Total Water Intake (g/day) of Females by Broad Age Category and Season (All Regions) ^§◆^

Season | Age (yr) | Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Season | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Spring | < 1 | 33 | 39.6 | 1111 | 402 | 70 | * | * | * | 832 | 1066 | 1306 | * | * | *
| 1–10 | 536 | 716.2 | 1507 | 479 | 21 | 608 | 821 | 949 | 1171 | 1452 | 1764 | 2183 | 2393 | 2910
| 11–19 | 675 | 876.6 | 1770 | 593 | 23 | 683 | 983 | 1147 | 1366 | 1695 | 2074 | 2530 | 2759 | 3503
| 20–64 | 2139 | 2833.2 | 2003 | 676 | 15 | 780 | 1051 | 1220 | 1528 | 1933 | 2369 | 2870 | 3182 | 4053
| 65+ | 444 | 575.5 | 2082 | 623 | 30 | 812 | 1173 | 1349 | 1631 | 2038 | 2478 | 2859 | 3126 | 3749
| All | 3827 | 5041.1 | 1894 | 660 | 11 | 717 | 981 | 1144 | 1424 | 1814 | 2269 | 2735 | 3084 | 3904
Summer | < 1 | 44 | 58.4 | 1180 | 337 | 51 | * | * | 799 | 948 | 1123 | 1384 | 1544 | * | *
| 1–10 | 666 | 788.8 | 1574 | 489 | 19 | 668 | 882 | 1014 | 1225 | 1515 | 1867 | 2197 | 2489 | 3220
| 11–19 | 714 | 871.8 | 1834 | 632 | 24 | 600 | 961 | 1086 | 1392 | 1772 | 2200 | 2635 | 2917 | 3798
| 20–64 | 1375 | 3250.3 | 2123 | 736 | 20 | 833 | 1123 | 1285 | 1606 | 2037 | 2500 | 3067 | 3447 | 4378
| 65+ | 328 | 620.9 | 2164 | 697 | 38 | * | 1206 | 1334 | 1681 | 2056 | 2553 | 3143 | 3424 | *
| All | 3127 | 5590.2 | 1995 | 718 | 13 | 774 | 1015 | 1178 | 1484 | 1901 | 2393 | 2935 | 3297 | 4147
Fall | < 1 | 61 | 59.3 | 1155 | 336 | 43 | * | * | 629 | 958 | 1126 | 1360 | 1614 | * | *
| 1–10 | 779 | 812.2 | 1533 | 513 | 18 | 564 | 810 | 974 | 1177 | 1445 | 1820 | 2230 | 2545 | 2983
| 11–19 | 808 | 883.5 | 1745 | 567 | 20 | 665 | 946 | 1068 | 1350 | 1680 | 2083 | 2537 | 2699 | 3236
| 20–64 | 1661 | 3358.8 | 2030 | 724 | 18 | 841 | 1084 | 1223 | 1525 | 1923 | 2392 | 2951 | 3385 | 4233
| 65+ | 413 | 649.2 | 2027 | 661 | 33 | 861 | 1035 | 1227 | 1599 | 1960 | 2395 | 2970 | 3306 | 3854
| All | 3722 | 5763.0 | 1907 | 694 | 11 | 711 | 977 | 1125 | 1417 | 1801 | 2285 | 2797 | 3186 | 3927
Winter | < 1 | 65 | 67.6 | 1121 | 315 | 39 | * | * | 776 | 869 | 1118 | 1271 | 1626 | * | *
| 1–10 | 770 | 813.1 | 1478 | 482 | 17 | 620 | 755 | 894 | 1145 | 1447 | 1754 | 2092 | 2349 | 2975
| 11–19 | 760 | 829.7 | 1742 | 578 | 21 | 633 | 871 | 1112 | 1364 | 1658 | 2059 | 2516 | 2830 | 3406
| 20–64 | 1533 | 3134.7 | 2017 | 714 | 18 | 679 | 1032 | 1201 | 1529 | 1920 | 2407 | 2917 | 3287 | 4187
| 65+ | 389 | 598.3 | 1946 | 605 | 31 | 637 | 1122 | 1267 | 1542 | 1853 | 2285 | 2751 | 3036 | 3714
| All | 3517 | 5443.4 | 1876 | 683 | 12 | 637 | 924 | 1101 | 1407 | 1784 | 2249 | 2775 | 3085 | 3851
All Seasons | All | 14193 | 21837.6 | 1919 | 691 | 6 | 697 | 972 | 1136 | 1433 | 1823 | 2299 | 2816 | 3166 | 4027

§ Does not include pregnant women, lactating women, or breast-fed children.

◆ Individual values may not add to totals due to rounding.

* Value not reported due to insufficient number of observations.

### B TOTAL WATER INTAKE (g/kg/day)

Set B. Table 10 Total Vater Intake (g/kg/day) by Broad Age Category and Sex (All Regions, All Seasons) ^§◆^

Sex | Age (yr) | Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Sex | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Both Sexes | < 1 | 403 | 444.3 | 163.1 | 63.3 | 3.2 | 63.9 | 86.1 | 98.5 | 120.0 | 152.5 | 190.9 | 238.4 | 274.0 | 408.6
| 1–10 | 5605 | 6354.1 | 75.3 | 32.2 | 0.4 | 25.9 | 34.4 | 40.6 | 52.3 | 69.2 | 92.0 | 117.7 | 135.5 | 179.4
| 11–19 | 5801 | 6824.9 | 37.5 | 14.5 | 0.2 | 12.0 | 18.0 | 21.4 | 27.3 | 35.4 | 45.5 | 56.8 | 64.4 | 81.1
| 20–64 | 11731 | 21744.9 | 32.6 | 12.5 | 0.1 | 11.5 | 16.1 | 18.9 | 24.0 | 30.7 | 39.1 | 48.8 | 56.1 | 71.7
| 65+ | 2541 | 4142.0 | 32.9 | 11.5 | 0.2 | 12.2 | 17.0 | 19.8 | 24.8 | 31.4 | 39.4 | 47.7 | 54.6 | 65.5
| All | 26081 | 39510.2 | 41.8 | 27.4 | 0.2 | 12.2 | 17.3 | 20.2 | 26.0 | 34.5 | 47.7 | 70.8 | 93.6 | 151.0
Males | < 1 | 200 | 219.4 | 153.0 | 52.9 | 3.7 | * | 86.1 | 97.2 | 114.9 | 146.2 | 178.8 | 222.2 | 247.7 | *
| 1–10 | 2854 | 3223.8 | 76.4 | 32.8 | 0.6 | 26.0 | 34.5 | 40.8 | 53.3 | 70.2 | 93.5 | 119.2 | 137.2 | 181.4
| 11–19 | 2844 | 3363.2 | 39.6 | 14.8 | 0.3 | 14.2 | 19.5 | 22.8 | 29.1 | 37.5 | 47.9 | 59.5 | 67.8 | 84.4
| 20–64 | 5023 | 9168.1 | 32.3 | 12.4 | 0.2 | 11.5 | 16.2 | 18.9 | 23.7 | 30.2 | 38.7 | 48.2 | 55.3 | 71.5
| 65+ | 967 | 1698.1 | 32.9 | 11.3 | 0.4 | 12.9 | 17.2 | 20.2 | 25.3 | 31.6 | 39.0 | 46.3 | 53.5 | 72.9
| All | 11888 | 17672.6 | 43.3 | 28.1 | 0.3 | 12.5 | 17.8 | 20.6 | 26.5 | 35.3 | 49.7 | 75.2 | 98.6 | 153.0
Females | < 1 | 203 | 225.0 | 172.9 | 70.7 | 5.0 | * | 87.2 | 101.4 | 124.2 | 160.4 | 207.6 | 264.0 | 305.7 | *
| 1–10 | 2751 | 3130.2 | 74.2 | 31.6 | 0.6 | 25.7 | 34.1 | 40.3 | 51.1 | 67.9 | 90.7 | 115.7 | 134.5 | 175.7
| 11–19 | 2957 | 3461.7 | 35.5 | 13.9 | 0.3 | 11.0 | 16.5 | 19.9 | 25.8 | 33.6 | 43.0 | 54.0 | 61.4 | 76.9
| 20–64 | 6708 | 12576.8 | 32.9 | 12.6 | 0.2 | 11.5 | 16.0 | 18.9 | 24.1 | 31.0 | 39.4 | 49.2 | 56.5 | 71.9
| 65+ | 1574 | 2443.9 | 32.8 | 11.6 | 0.3 | 11.2 | 16.8 | 19.5 | 24.4 | 31.2 | 39.7 | 48.1 | 54.9 | 63.8
| All | 14193 | 21837.6 | 40.7 | 26.8 | 0.2 | 11.8 | 16.8 | 20.0 | 25.7 | 34.0 | 46.2 | 66.4 | 88.9 | 148.0

§ Does not include pregnant women, lactating women, or breast-fed children.

◆ Individual values may not add to totals due to rounding.

* Value not reported due to insufficient number of observations.

Set B. Table 11 Total Water Intake (g/kg/day) by Fine Age Category and Sex (All Regions, All Seasons) ^§◆^

Sex | Age (yr) | Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Sex | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Both Sexes | < 0.5 | 182 | 201.2 | 189.0 | 73.5 | 5.4 | * | 96.3 | 114.5 | 137.5 | 174.5 | 223.9 | 279.6 | 353.0 | *
| 0.5–0.9 | 221 | 243.2 | 141.7 | 43.0 | 2.9 | * | 80.5 | 92.1 | 110.5 | 138.1 | 166.6 | 196.9 | 226.7 | *
| 1– 3 | 1498 | 1687.7 | 99.7 | 35.7 | 0.9 | 34.4 | 51.8 | 59.9 | 73.5 | 95.1 | 118.4 | 145.4 | 164.9 | 209.2
| 4– 6 | 1702 | 1923.9 | 77.7 | 27.6 | 0.7 | 28.4 | 41.5 | 46.8 | 58.4 | 73.9 | 92.6 | 114.3 | 127.9 | 164.2
| 7–10 | 2405 | 2742.4 | 58.7 | 20.9 | 0.4 | 22.8 | 30.4 | 35.0 | 43.6 | 55.8 | 70.2 | 85.8 | 97.4 | 121.1
| 11–14 | 2803 | 3146.9 | 41.9 | 15.6 | 0.3 | 14.2 | 20.5 | 23.7 | 30.9 | 39.9 | 50.2 | 63.1 | 71.7 | 89.1
| 15–19 | 2998 | 3677.9 | 33.8 | 12.3 | 0.2 | 11.6 | 16.9 | 19.7 | 25.4 | 32.2 | 40.6 | 49.9 | 56.4 | 71.3
| 20–44 | 7171 | 13444.5 | 32.1 | 12.5 | 0.1 | 11.2 | 15.8 | 18.5 | 23.3 | 30.1 | 38.6 | 48.5 | 55.4 | 70.8
| 45–64 | 4560 | 8300.4 | 33.5 | 12.5 | 0.2 | 12.4 | 16.9 | 19.7 | 24.9 | 31.7 | 39.9 | 49.3 | 57.2 | 73.1
| 65–74 | 1663 | 2740.2 | 32.9 | 11.5 | 0.3 | 12.6 | 17.0 | 19.9 | 24.7 | 31.3 | 39.1 | 47.9 | 55.3 | 65.5
| 75+ | 878 | 1401.8 | 32.9 | 11.4 | 0.4 | 10.9 | 17.0 | 19.6 | 24.9 | 31.5 | 39.9 | 47.2 | 53.3 | 64.8
| All | 26081 | 39510.2 | 41.8 | 27.4 | 0.2 | 12.2 | 17.3 | 20.2 | 26.0 | 34.5 | 47.7 | 70.8 | 93.6 | 151.0
Males | < 0.5 | 87 | 96.4 | 171.1 | 60.5 | 6.5 | * | 95.9 | 102.5 | 136.4 | 157.1 | 198.2 | 245.2 | 272.8 | *
| 0.5–0.9 | 113 | 122.9 | 138.8 | 41.0 | 3.9 | * | 70.4 | 95.9 | 109.6 | 136.3 | 160.7 | 186.2 | 208.5 | *
| 1– 3 | 775 | 879.6 | 101.1 | 36.6 | 1.3 | 34.5 | 53.8 | 61.4 | 74.4 | 96.1 | 119.5 | 147.7 | 165.6 | 221.4
| 4– 6 | 883 | 991.4 | 78.1 | 27.2 | 0.9 | 29.5 | 41.7 | 47.5 | 59.0 | 74.0 | 93.4 | 114.4 | 125.8 | 160.7
| 7–10 | 1196 | 1352.9 | 59.2 | 21.3 | 0.6 | 22.5 | 30.2 | 34.7 | 43.6 | 56.2 | 71.4 | 87.8 | 98.8 | 124.8
| 11–14 | 1395 | 1571.8 | 44.3 | 15.8 | 0.4 | 17.0 | 22.1 | 26.0 | 33.2 | 41.9 | 53.2 | 66.0 | 73.2 | 91.0
| 15–19 | 1449 | 1791.4 | 35.5 | 12.5 | 0.3 | 12.7 | 18.5 | 21.2 | 26.4 | 33.9 | 42.1 | 52.0 | 58.7 | 73.5
| 20–44 | 3146 | 5702.7 | 32.0 | 12.7 | 0.2 | 11.2 | 15.8 | 18.6 | 23.1 | 29.7 | 38.6 | 48.1 | 55.8 | 72.2
| 45–64 | 1877 | 3465.4 | 32.7 | 11.8 | 0.3 | 12.6 | 17.3 | 19.5 | 24.5 | 30.9 | 38.9 | 48.5 | 54.3 | 71.1
| 65–74 | 656 | 1172.3 | 32.7 | 11.3 | 0.4 | 12.6 | 16.8 | 20.2 | 25.0 | 31.6 | 38.0 | 46.5 | 53.5 | 72.9
| 75+ | 311 | 525.8 | 33.3 | 11.3 | 0.6 | * | 18.3 | 20.0 | 25.6 | 31.7 | 40.2 | 46.2 | 54.9 | *
| All | 11888 | 17672.6 | 43.3 | 28.1 | 0.3 | 12.5 | 17.8 | 20.6 | 26.5 | 35.3 | 49.7 | 75.2 | 98.6 | 153.0
Females | < 0.5 | 95 | 104.7 | 205.4 | 80.5 | 8.3 | * | 107.0 | 121.6 | 146.8 | 186.4 | 240.1 | 305.7 | 357.9 | *
| 0.5–0.9 | 108 | 120.2 | 144.6 | 45.1 | 4.3 | * | 82.0 | 89.5 | 112.3 | 140.6 | 173.5 | 207.6 | 235.5 | *
| 1– 3 | 723 | 808.2 | 98.2 | 34.7 | 1.3 | 34.2 | 50.2 | 57.7 | 73.0 | 94.5 | 117.6 | 145.1 | 161.1 | 200.6
| 4– 6 | 819 | 932.5 | 77.3 | 28.1 | 1.0 | 28.0 | 41.3 | 45.6 | 57.2 | 73.5 | 92.0 | 114.2 | 130.0 | 167.6
| 7–10 | 1209 | 1389.5 | 58.2 | 20.5 | 0.6 | 24.1 | 30.4 | 35.3 | 43.7 | 55.4 | 69.3 | 84.5 | 95.3 | 115.7
| 11–14 | 1408 | 1575.1 | 39.5 | 15.0 | 0.4 | 11.3 | 19.0 | 22.4 | 29.2 | 37.8 | 47.5 | 59.9 | 66.7 | 82.6
| 15–19 | 1549 | 1886.5 | 32.2 | 11.9 | 0.3 | 10.6 | 15.4 | 18.4 | 24.1 | 30.7 | 38.6 | 47.5 | 54.3 | 66.9
| 20–44 | 4025 | 7741.7 | 32.2 | 12.3 | 0.2 | 11.2 | 15.8 | 18.4 | 23.5 | 30.4 | 38.6 | 48.6 | 55.3 | 69.8
| 45–64 | 2683 | 4835.1 | 34.1 | 12.9 | 0.2 | 12.3 | 16.7 | 19.7 | 25.2 | 32.2 | 40.6 | 50.0 | 59.4 | 75.2
| 65–74 | 1007 | 1567.9 | 33.0 | 11.7 | 0.4 | 12.7 | 17.0 | 19.6 | 24.4 | 31.1 | 39.9 | 48.3 | 56.5 | 63.8
| 75+ | 567 | 876.0 | 32.6 | 11.5 | 0.5 | 10.0 | 16.7 | 19.5 | 24.7 | 31.3 | 39.5 | 47.7 | 52.8 | 62.9
| All | 14193 | 21837.6 | 40.7 | 26.8 | 0.2 | 11.8 | 16.8 | 20.0 | 25.7 | 34.0 | 46.2 | 66.4 | 88.9 | 148.0

§ Does not include pregnant women, lactating women, or breast-fed children.

◆ Individual values may not add to totals due to rounding.

* Value not reported due to insufficient number of observations.

Set B. Table 12 Total Water Intake (g/kg/day) of Pregnant Women, Lactating Women, and Breast-fed Children (All Regions, All Seasons)

| Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
| Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 5 | 10 | 25 | 50 | 75 | 90 | 95
Pregnant women | 188 | 327.5 | 32.1 | 11.8 | 0.9 | 16.4 | 17.8 | 22.8 | 30.5 | 40.4 | 48.9 | 53.5
Lactating women | 77 | 151.2 | 37.0 | 11.6 | 1.3 | 19.6 | 21.8 | 28.4 | 35.1 | 45.0 | 53.7 | 59.2
Breast-fed children^§^
Both sexes
All ages | 100 | 121.0 | 55.7 | 48.1 | 4.8 | 0.0 | 0.0 | 14.0 | 48.8 | 78.8 | 122.3 | 155.4
< 0.5 yr | 62 | 74.4 | 51.9 | 55.3 | 7.0 | * | 0.0 | 0.0 | 34.7 | 87.2 | 132.6 | *
≥ 0.5 yr | 38 | 46.6 | 61.8 | 33.4 | 5.4 | * | 20.0 | 42.8 | 57.6 | 78.8 | 110.5 | *
Males
All ages | 42 | 49.4 | 50.7 | 45.4 | 7.0 | * | 0.0 | 12.9 | 34.7 | 78.8 | 114.7 | *
< 0.5 yr | 28 | 34.0 | 48.0 | 50.6 | 9.6 | * | * | 0.0 | 32.1 | 102.4 | * | *
≥ 0.5 yr | 14 | 15.5 | * | * | * | * | * | 20.0 | 64.0 | 78.8 | * | *
Females
All ages | 58 | 71.6 | 59.2 | 49.9 | 6.6 | * | 0.0 | 25.1 | 52.9 | 78.1 | 130.8 | *
< 0.5 yr | 34 | 40.5 | 55.2 | 59.4 | 10.2 | * | * | 0.0 | 44.1 | 75.7 | * | *
≥ 0.5 yr | 24 | 31.1 | * | * | * | * | * | 43.5 | 57.6 | 78.1 | * | *

§ Total water intake of breast-fed children does not include the contribution of breast milk.

* Value not reported due to insufficient number of observations.

0.0 Less than 0.05 g/kg/day.

Set B. Table 13 Total Water Intake (g/kg/day) of Both Sexes by Broad Age Category and Geographic Region (All Seasons) ^§◆^

Region | Age (yr) | Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Region | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Northeast | < 1 | 84 | 95.7 | 162.1 | 61.1 | 6.7 | * | 98.4 | 104.8 | 127.9 | 146.2 | 182.8 | 227.3 | 266.7 | *
| 1–10 | 1323 | 1519.2 | 69.2 | 29.9 | 0.8 | 22.1 | 32.7 | 38.1 | 48.4 | 62.8 | 84.4 | 109.4 | 123.5 | 168.2
| 11–19 | 1324 | 1565.0 | 34.8 | 13.3 | 0.4 | 10.6 | 16.8 | 19.9 | 25.5 | 32.9 | 42.0 | 51.9 | 60.3 | 72.3
| 20–64 | 2883 | 5548.0 | 30.2 | 11.0 | 0.2 | 11.1 | 15.9 | 18.2 | 22.4 | 28.7 | 36.0 | 43.9 | 50.0 | 65.8
| 65. | 584 | 959.4 | 31.0 | 10.8 | 0.4 | 12.0 | 16.6 | 19.4 | 23.7 | 30.0 | 35.9 | 43.4 | 49.4 | 71.1
| All | 6198 | 9687.3 | 38.5 | 25.2 | 0.3 | 11.5 | 16.6 | 19.1 | 24.4 | 32.0 | 43.1 | 63.7 | 84.4 | 137.5
Midwest | < 1 | 101 | 114.5 | 165.7 | 60.6 | 6.0 | * | 84.1 | 101.4 | 119.2 | 155.9 | 198.2 | 247.7 | 288.1 | *
| 1–10 | 1505 | 1700.8 | 76.5 | 32.3 | 0.8 | 26.7 | 36.2 | 41.1 | 53.2 | 71.0 | 94.1 | 116.9 | 136.0 | 166.3
| 11–19 | 1611 | 1908.0 | 37.8 | 14.7 | 0.4 | 12.6 | 17.9 | 21.3 | 27.4 | 35.8 | 45.9 | 57.5 | 65.9 | 83.3
| 20–64 | 2972 | 5593.4 | 32.5 | 11.9 | 0.2 | 12.5 | 16.7 | 19.1 | 24.2 | 30.8 | 38.8 | 48.1 | 54.0 | 69.0
| 65+ | 604 | 1037.5 | 33.2 | 11.3 | 0.5 | 13.6 | 17.5 | 20.5 | 24.9 | 31.8 | 39.5 | 47.7 | 56.6 | 64.7
| All | 6793 | 10354.2 | 42.3 | 27.7 | 0.3 | 12.9 | 17.6 | 20.6 | 26.3 | 34.9 | 47.9 | 72.5 | 95.8 | 152.1
South | < 1 | 150 | 146.3 | 158.5 | 62.1 | 5.1 | * | 77.0 | 89.5 | 115.9 | 152.5 | 183.8 | 229.6 | 261.3 | *
| 1–10 | 1928 | 2006.8 | 76.0 | 32.2 | 0.7 | 25.7 | 34.2 | 40.9 | 53.0 | 70.0 | 92.9 | 118.4 | 137.3 | 181.9
| 11–19 | 1982 | 2154.1 | 38.5 | 14.7 | 0.3 | 13.8 | 18.9 | 22.1 | 28.3 | 36.2 | 46.4 | 58.1 | 66.2 | 83.6
| 20–64 | 3980 | 6642.8 | 33.1 | 12.9 | 0.2 | 10.8 | 15.7 | 18.7 | 24.1 | 30.9 | 39.8 | 49.6 | 57.7 | 73.0
| 65+ | 970 | 1448.1 | 32.8 | 11.8 | 0.4 | 11.7 | 16.2 | 18.9 | 24.5 | 30.9 | 39.9 | 48.4 | 54.6 | 64.8
| All | 9010 | 12398.1 | 42.4 | 27.5 | 0.3 | 11.7 | 17.1 | 20.2 | 26.3 | 35.2 | 48.6 | 71.7 | 94.1 | 152.5
West | < 1 | 68 | 87.7 | 168.4 | 71.1 | 8.6 | * | * | 99.2 | 120.7 | 149.9 | 196.9 | 264.0 | * | *
| 1–10 | 849 | 1127.2 | 80.5 | 33.9 | 1.2 | 27.2 | 36.6 | 43.6 | 56.1 | 74.7 | 97.5 | 127.6 | 145.9 | 182.2
| 11–19 | 884 | 1197.8 | 38.8 | 14.9 | 0.5 | 11.2 | 18.3 | 22.0 | 28.3 | 36.5 | 47.0 | 58.2 | 66.8 | 83.5
| 20–64 | 1896 | 3960.7 | 35.4 | 13.8 | 0.3 | 12.7 | 17.1 | 20.4 | 25.9 | 33.0 | 42.6 | 53.7 | 62.2 | 79.8
| 65+ | 383 | 697.0 | 35.1 | 11.5 | 0.6 | 14.5 | 19.3 | 21.7 | 27.1 | 33.8 | 41.4 | 50.8 | 56.8 | 67.0
| All | 4080 | 7070.4 | 44.8 | 29.3 | 0.5 | 12.8 | 18.4 | 21.6 | 28.0 | 37.0 | 51.3 | 76.0 | 99.0 | 163.4
All Regions | All | 26081 | 39510.2 | 41.8 | 27.4 | 0.2 | 12.2 | 17.3 | 20.2 | 26.0 | 34.5 | 47.7 | 70.8 | 93.6 | 151.0

§ Does not include pregnant women, lactating women, or breast-fed children.

◆ Individual values may not add to totals due to rounding.

* Value not reported due to insufficient number of observations.

Set B. Table 14 Total Water Intake (g/kg/day) of Males by Broad Age Category and Geographic Region (All Seaaons) ^§◆^

Region | Age (yr) | Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Region | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Northeast | < 1 | 36 | 38.9 | 164.7 | 70.5 | 11.8 | * | * | 109.4 | 132.9 | 145.8 | 179.0 | 236.9 | * | *
| 1–10 | 674 | 765.4 | 69.9 | 30.1 | 1.2 | 21.7 | 32.4 | 39.2 | 49.2 | 63.9 | 86.1 | 111.2 | 125.7 | 164.7
| 11–19 | 660 | 772.9 | 36.2 | 13.6 | 0.5 | 11.8 | 18.4 | 21.2 | 26.3 | 34.6 | 43.1 | 53.3 | 61.8 | 73.0
| 20–64 | 1226 | 2310.2 | 29.2 | 10.8 | 0.3 | 9.7 | 15.2 | 17.3 | 21.4 | 27.9 | 34.6 | 42.9 | 49.1 | 60.6
| 65+ | 217 | 375.2 | 31.1 | 11.5 | 0.8 | * | 16.5 | 19.3 | 23.6 | 30.2 | 35.5 | 42.7 | 49.2 | *
| All | 2813 | 4262.6 | 39.2 | 26.3 | 0.5 | 10.7 | 16.3 | 18.9 | 24.1 | 32.0 | 44.2 | 67.2 | 89.7 | 139.8
Midwest | < 1 | 53 | 59.5 | 150.1 | 44.4 | 6.1 | * | * | 96.7 | 113.3 | 152.9 | 174.8 | 212.1 | * | *
| 1–10 | 796 | 903.3 | 77.7 | 34.0 | 1.2 | 25.6 | 34.5 | 40.7 | 54.6 | 71.8 | 95.3 | 118.8 | 138.0 | 189.0
| 11–19 | 785 | 942.5 | 39.9 | 15.0 | 0.5 | 14.6 | 19.9 | 22.8 | 29.5 | 37.5 | 48.2 | 59.9 | 70.6 | 84.5
| 20–64 | 1325 | 2442.6 | 32.1 | 11.9 | 0.3 | 12.5 | 16.8 | 19.0 | 23.8 | 30.3 | 38.2 | 47.3 | 53.4 | 69.6
| 65+ | 238 | 440.3 | 32.6 | 11.3 | 0.7 | * | 17.7 | 20.7 | 24.9 | 30.4 | 38.4 | 46.9 | 51.7 | *
| All | 3197 | 4788.2 | 43.8 | 28.5 | 0.5 | 12.9 | 18.3 | 20.9 | 26.6 | 35.4 | 50.0 | 77.6 | 101.2 | 155.9
South | < 1 | 74 | 72.3 | 151.9 | 54.7 | 6.4 | * | 68.5 | 86.5 | 112.5 | 148.7 | 185.2 | 230.5 | 260.9 | *
| 1–10 | 974 | 1005.9 | 76.8 | 32.3 | 1.0 | 27.4 | 34.9 | 41.3 | 54.6 | 70.9 | 93.2 | 119.0 | 137.4 | 193.2
| 11–19 | 969 | 1071.3 | 40.5 | 15.0 | 0.5 | 15.7 | 20.2 | 23.2 | 29.6 | 38.6 | 48.6 | 60.1 | 67.6 | 87.9
| 20–64 | 1645 | 2707.0 | 33.6 | 13.1 | 0.3 | 11.1 | 16.5 | 19.6 | 24.5 | 31.2 | 40.4 | 51.0 | 58.2 | 75.1
| 65+ | 360 | 577.4 | 33.6 | 11.4 | 0.6 | * | 17.0 | 19.9 | 25.7 | 32.3 | 40.5 | 47.9 | 53.5 | *
| All | 4022 | 5433.9 | 44.5 | 28.2 | 0.4 | 12.6 | 18.5 | 21.3 | 27.4 | 36.6 | 51.8 | 76.5 | 98.2 | 160.4
West | < 1 | 37 | 48.6 | 148.9 | 42.5 | 7.0 | * | * | 98.7 | 120.7 | 143.9 | 173.5 | 201.5 | * | *
| 1–10 | 410 | 549.2 | 82.7 | 33.8 | 1.7 | 29.9 | 39.3 | 44.4 | 58.3 | 77.5 | 101.4 | 128.4 | 146.6 | 180.9
| 11–19 | 430 | 576.5 | 42.0 | 15.1 | 0.7 | 16.5 | 21.6 | 24.9 | 31.5 | 39.9 | 49.4 | 63.3 | 71.7 | 85.7
| 20–64 | 827 | 1708.3 | 34.5 | 12.9 | 0.4 | 12.7 | 17.6 | 20.0 | 25.6 | 32.0 | 41.9 | 51.6 | 61.4 | 71.7
| 65+ | 152 | 305.1 | 34.5 | 10.5 | 0.9 | * | 19.7 | 22.1 | 27.5 | 34.1 | 39.9 | 46.5 | 54.9 | *
| All | 1856 | 3187.7 | 45.9 | 29.1 | 0.7 | 13.1 | 19.1 | 22.0 | 28.3 | 37.7 | 52.2 | 79.5 | 107.8 | 164.6
All Regions | All | 11888 | 17672.6 | 43.3 | 28.1 | 0.3 | 12.5 | 17.8 | 20.6 | 26.5 | 35.3 | 49.7 | 75.2 | 98.6 | 153.0

§ Does not include breast-fed children.

◆ Individual values may not add to totals due to rounding.

* Value not reported due to insufficient number of observations.

Set B. Table 15 Total Vater Intake (g/kg/day) of Females by Broad Age Category and Geographic Region (All Seasons) ^§◆^

Region | Age (yr) | Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Region | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Northeast | < 1 | 48 | 56.8 | 160.3 | 54.4 | 7.9 | * | * | 104.8 | 120.0 | 151.0 | 193.2 | 227.3 | * | *
| 1–10 | 649 | 753.8 | 68.6 | 29.8 | 1.2 | 24.5 | 32.9 | 38.1 | 47.7 | 61.8 | 83.0 | 108.6 | 123.4 | 180.9
| 11–19 | 664 | 792.1 | 33.4 | 12.8 | 0.5 | 9.4 | 16.1 | 18.8 | 24.8 | 31.4 | 41.1 | 49.5 | 57.9 | 69.8
| 20–64 | 1657 | 3237.9 | 31.0 | 11.1 | 0.3 | 12.7 | 16.3 | 18.7 | 23.1 | 29.6 | 36.7 | 44.8 | 51.0 | 67.7
| 65+ | 367 | 584.2 | 31.0 | 10.3 | 0.5 | * | 16.6 | 19.4 | 23.8 | 29.4 | 37.1 | 44.1 | 49.4 | *
| All | 3385 | 5424.8 | 37.9 | 24.2 | 0.4 | 12.5 | 16.7 | 19.6 | 24.6 | 32.1 | 42.2 | 61.2 | 80.3 | 133.7
Midwest | < 1 | 48 | 55.0 | 182.5 | 70.8 | 10.2 | * | * | 101.4 | 127.3 | 168.3 | 237.9 | 288.1 | * | *
| 1–10 | 709 | 797.5 | 75.2 | 30.1 | 1.1 | 26.9 | 37.8 | 41.6 | 52.3 | 70.6 | 92.4 | 115.3 | 134.8 | 161.6
| 11–19 | 826 | 965.5 | 35.8 | 14.2 | 0.5 | 11.5 | 17.0 | 20.1 | 25.7 | 34.1 | 43.4 | 54.2 | 63.2 | 82.4
| 20–64 | 1647 | 3150.8 | 32.8 | 11.9 | 0.3 | 12.5 | 16.6 | 19.1 | 24.5 | 31.1 | 39.4 | 48.9 | 54.6 | 68.8
| 65+ | 366 | 597.2 | 33.7 | 11.3 | 0.6 | * | 17.5 | 20.2 | 25.0 | 32.7 | 40.7 | 47.8 | 56.7 | *
| All | 3596 | 5566.0 | 41.0 | 26.9 | 0.4 | 12.7 | 17.3 | 20.2 | 26.1 | 34.5 | 46.3 | 66.6 | 89.9 | 148.2
South | < 1 | 76 | 74.0 | 164.9 | 68.3 | 7.8 | * | 87.2 | 89.5 | 120.1 | 160.3 | 182.9 | 226.7 | 331.2 | *
| 1–10 | 954 | 1000.9 | 75.2 | 32.0 | 1.0 | 24.6 | 32.9 | 40.5 | 51.2 | 68.9 | 92.6 | 117.8 | 137.3 | 174.6
| 11–19 | 1013 | 1082.8 | 36.6 | 14.1 | 0.4 | 12.2 | 17.4 | 20.8 | 27.0 | 34.2 | 43.7 | 56.1 | 63.4 | 78.0
| 20–64 | 2335 | 3935.7 | 32.7 | 12.7 | 0.3 | 10.6 | 15.1 | 18.2 | 23.7 | 30.8 | 39.3 | 49.1 | 57.1 | 69.4
| 65+ | 610 | 870.7 | 32.2 | 12.1 | 0.5 | 11.1 | 15.5 | 18.3 | 23.5 | 30.1 | 39.4 | 49.0 | 54.9 | 62.9
| All | 4988 | 6964.1 | 40.7 | 26.8 | 0.4 | 11.2 | 16.0 | 19.4 | 25.5 | 34.0 | 46.4 | 67.3 | 90.3 | 148.9
West | < 1 | 31 | 39.2 | 192.7 | 90.2 | 16.2 | * | * | * | 126.3 | 177.4 | 243.7 | * | * | *
| 1–10 | 439 | 578.0 | 78.4 | 33.9 | 1.6 | 26.6 | 35.3 | 42.2 | 54.5 | 71.8 | 93.3 | 126.7 | 145.5 | 182.2
| 11–19 | 454 | 621.3 | 35.8 | 14.0 | 0.7 | 10.2 | 15.4 | 19.7 | 25.8 | 34.5 | 43.5 | 54.3 | 60.7 | 77.4
| 20–64 | 1069 | 2252.5 | 36.2 | 14.3 | 0.4 | 13.1 | 16.7 | 20.6 | 26.3 | 33.8 | 43.3 | 55.9 | 62.7 | 83.0
| 65+ | 231 | 391.9 | 35.6 | 12.2 | 0.8 | * | 19.3 | 21.0 | 27.1 | 33.6 | 43.2 | 52.3 | 58.6 | *
| All | 2224 | 3882.9 | 43.9 | 29.5 | 0.6 | 12.3 | 17.8 | 21.1 | 27.7 | 36.6 | 50.6 | 71.9 | 93.0 | 152.5
All Regions | All | 14193 | 21837.6 | 40.7 | 26.8 | 0.2 | 11.8 | 16.8 | 20.0 | 25.7 | 34.0 | 46.2 | 66.4 | 88.9 | 148.0

§ Does not include pregnant women_r_ lactating women, or breast-fed children.

◆ Individual values may not add to totals due to rounding.

* Value not reported due to insufficient number of observations.

Set B. Table 16 Total Water Intake (g/kg/day) of Both Sexes by Broad Age Category and Season (All Regions) ^§◆^

Season | Age (yr) | Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Season | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Spring | < 1 | 63 | 78.9 | 153.5 | 64.8 | 8.2 | * | * | 95.9 | 113.2 | 139.5 | 175.2 | 226.7 | * | *
| 1–10 | 1117 | 1511.9 | 74.8 | 31.6 | 0.9 | 24.5 | 32.8 | 39.5 | 52.3 | 68.6 | 93.7 | 117.8 | 132.7 | 166.9
| 11–19 | 1332 | 1760.4 | 37.7 | 14.5 | 0.4 | 11.2 | 18.4 | 21.9 | 27.6 | 35.7 | 44.6 | 56.6 | 65.1 | 87.0
| 20–64 | 3997 | 5258.9 | 32.3 | 12.1 | 0.2 | 11.6 | 16.3 | 18.7 | 23.7 | 30.4 | 38.8 | 47.9 | 54.6 | 69.2
| 65+ | 770 | 996.5 | 33.5 | 11.3 | 0.4 | 14.3 | 18.3 | 20.7 | 25.2 | 31.4 | 40.2 | 48.5 | 54.1 | 62.8
| All | 7279 | 9606.6 | 41.1 | 25.6 | 0.3 | 12.2 | 17.5 | 20.2 | 26.0 | 34.5 | 46.7 | 68.7 | 92.3 | 139.7
Summer | < 1 | 107 | 130.1 | 164.9 | 62.9 | 6.1 | * | 94.4 | 101.4 | 124.6 | 153.8 | 188.7 | 235.5 | 302.5 | *
| 1–10 | 1321 | 1568.1 | 77.5 | 31.6 | 0.9 | 28.7 | 36.3 | 42.2 | 54.8 | 71.9 | 94.6 | 119.0 | 136.0 | 173.0
| 11–19 | 1356 | 1672.0 | 39.4 | 15.7 | 0.4 | 12.2 | 18.2 | 21.4 | 28.0 | 36.6 | 48.4 | 60.4 | 69.3 | 85.7
| 20–64 | 2327 | 5534.3 | 34.1 | 13.2 | 0.3 | 12.1 | 16.7 | 19.5 | 24.9 | 31.8 | 41.0 | 51.7 | 59.4 | 77.1
| 65+ | 513 | 1025.1 | 35.3 | 12.1 | 0.5 | 14.9 | 18.2 | 21.0 | 26.9 | 33.8 | 41.2 | 51.7 | 59.2 | 72.9
| All | 5624 | 9929.6 | 43.7 | 28.3 | 0.4 | 12.9 | 17.9 | 21.0 | 27.2 | 36.1 | 50.4 | 74.2 | 96.6 | 153.5
Fall | < 1 | 108 | 109.7 | 173.8 | 66.0 | 6.4 | * | 86.1 | 104.8 | 132.9 | 166.6 | 196.9 | 260.9 | 305.7 | *
| 1–10 | 1619 | 1648.4 | 75.3 | 32.2 | 0.8 | 27.4 | 35.4 | 41.4 | 52.5 | 69.0 | 90.5 | 115.9 | 138.6 | 182.7
| 11–19 | 1584 | 1717.0 | 36.9 | 13.8 | 0.3 | 12.9 | 18.3 | 21.1 | 27.1 | 34.8 | 44.5 | 55.4 | 63.3 | 77.7
| 20–64 | 2692 | 5444.0 | 32.2 | 12.5 | 0.2 | 11.7 | 15.9 | 18.7 | 23.7 | 30.2 | 38.5 | 47.9 | 55.5 | 73.9
| 65+ | 632 | 1073.3 | 31.8 | 11.4 | 0.5 | 11.7 | 15.8 | 19.6 | 23.9 | 30.1 | 37.8 | 45.8 | 53.3 | 66.6
| All | 6635 | 9992.4 | 41.6 | 28.1 | 0.3 | 12.2 | 17.0 | 20.1 | 25.8 | 34.0 | 47.1 | 70.9 | 92.6 | 156.0
Winter | < 1 | 125 | 125.7 | 157.7 | 59.5 | 5.3 | * | 70.4 | 93.8 | 114.2 | 150.7 | 198.2 | 238.4 | 273.7 | *
| 1–10 | 1548 | 1625.7 | 73.8 | 33.3 | 0.8 | 22.8 | 33.7 | 39.4 | 50.2 | 66.8 | 89.6 | 116.9 | 135.9 | 188.6
| 11–19 | 1529 | 1675.6 | 36.2 | 13.6 | 0.3 | 11.9 | 17.3 | 21.1 | 26.5 | 34.4 | 43.7 | 54.5 | 61.0 | 74.9
| 20–64 | 2715 | 5507.7 | 31.9 | 11.9 | 0.2 | 11.1 | 15.7 | 18.6 | 23.4 | 30.4 | 38.4 | 47.0 | 54.1 | 68.6
| 65+ | 626 | 1047.1 | 31.0 | 10.6 | 0.4 | 11.1 | 15.9 | 18.3 | 23.1 | 29.8 | 38.0 | 45.3 | 49.7 | 59.5
| All | 6543 | 9981.8 | 41.0 | 27.4 | 0.3 | 11.6 | 16.8 | 19.7 | 25.4 | 33.8 | 46.1 | 68.4 | 91.6 | 154.1
All Seasons | All | 26081 | 39510.2 | 41.8 | 27.4 | 0.2 | 12.2 | 17.3 | 20.2 | 26.0 | 34.5 | 47.7 | 70.8 | 93.6 | 151.0

§ Does not include pregnant women, lactating women, or breast-fed children.

◆ Individual values may not add to totals due to rounding.

* Value not reported due to insufficient number of observations.

Set B. Table 17 Total Water Intake (g/kg/day) of Males by Broad Age Category and Season (All Regions) ^§◆^

Season | Age (yr) | Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Season | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Spring | < 1 | 30 | 39.3 | 144.0 | 36.0 | 6.6 | * | * | * | 113.8 | 139.7 | 162.4 | * | * | *
| 1–10 | 581 | 795.7 | 75.7 | 32.3 | 1.3 | 23.4 | 33.0 | 40.0 | 53.2 | 68.3 | 94.8 | 118.4 | 135.5 | 166.9
| 1–19 | 657 | 883.8 | 40.2 | 15.0 | 0.6 | 16.2 | 20.3 | 23.6 | 30.1 | 37.4 | 48.0 | 59.5 | 68.7 | 91.2
| 0–64 | 1858 | 2425.7 | 32.4 | 12.1 | 0.3 | 11.7 | 16.8 | 19.0 | 23.8 | 30.3 | 39.0 | 48.1 | 54.0 | 69.6
| 65+ | 326 | 421.0 | 33.1 | 10.8 | 0.6 | * | 18.7 | 21.1 | 25.5 | 31.4 | 39.2 | 46.8 | 53.2 | *
| All | 3452 | 4565.5 | 42.5 | 25.9 | 0.4 | 13.2 | 18.3 | 20.8 | 26.5 | 35.5 | 48.8 | 72.4 | 97.0 | 145.5
Summer | < 1 | 63 | 71.6 | 158.9 | 61.5 | 7.7 | * | * | 102.4 | 118.5 | 145.5 | 183.9 | 223.9 | * | *
| 1–10 | 655 | 779.4 | 77.8 | 31.5 | 1.2 | 29.1 | 35.4 | 43.4 | 55.7 | 72.2 | 94.5 | 119.5 | 135.6 | 171.7
| 1–19 | 642 | 800.2 | 42.3 | 16.4 | 0.6 | 16.1 | 20.5 | 23.1 | 29.7 | 39.6 | 51.6 | 65.2 | 73.7 | 87.9
| 0–64 | 952 | 2284.1 | 34.3 | 13.7 | 0.4 | 10.7 | 16.4 | 19.3 | 24.7 | 31.9 | 41.4 | 52.6 | 60.9 | 78.4
| 65+ | 185 | 404.2 | 36.2 | 12.5 | 0.9 | * | 18.4 | 21.7 | 28.3 | 34.8 | 41.2 | 51.6 | 59.6 | *
| All | 2497 | 4339.5 | 45.8 | 29.6 | 0.6 | 12.4 | 18.5 | 21.5 | 27.7 | 37.4 | 53.9 | 79.4 | 103.5 | 157.1
Fall | < 1 | 47 | 50.4 | 153.1 | 49.5 | 7.2 | * | * | 96.3 | 124.3 | 148.1 | 174.2 | 230.5 | * | *
| 1–10 | 840 | 836.1 | 76.3 | 32.8 | 1.1 | 28.8 | 36.0 | 41.8 | 52.9 | 69.5 | 90.8 | 117.9 | 140.0 | 193.6
| 1–19 | 776 | 833.4 | 39.0 | 13.9 | 0.5 | 14.6 | 19.4 | 22.5 | 28.8 | 37.6 | 46.8 | 58.3 | 66.5 | 79.4
| 0–64 | 1031 | 2085.3 | 31.2 | 12.1 | 0.4 | 11.7 | 15.5 | 18.2 | 22.9 | 29.4 | 37.6 | 46.3 | 52.6 | 69.8
| 65+ | 219 | 424.1 | 32.2 | 11.5 | 0.8 | * | 17.0 | 21.0 | 24.7 | 30.2 | 37.0 | 44.5 | 53.1 | *
| All | 2913 | 4229.3 | 43.2 | 28.5 | 0.5 | 12.6 | 17.3 | 20.3 | 26.3 | 34.7 | 49.4 | 76.2 | 98.4 | 156.6
Winter | < 1 | 60 | 58.1 | 151.7 | 54.1 | 7.0 | * | * | 86.5 | 106.4 | 145.7 | 187.3 | 236.9 | * | *
| 1–10 | 778 | 812.6 | 75.9 | 34.4 | 1.2 | 21.7 | 34.3 | 39.4 | 51.5 | 70.5 | 92.5 | 120.1 | 137.9 | 195.8
| 1–19 | 769 | 845.8 | 37.0 | 13.4 | 0.5 | 12.7 | 18.6 | 21.7 | 27.1 | 35.6 | 44.9 | 54.9 | 62.2 | 76.5
| 0–64 | 1182 | 2373.0 | 31.2 | 11.2 | 0.3 | 11.5 | 16.0 | 18.8 | 23.3 | 29.6 | 37.2 | 45.6 | 52.3 | 66.5
| 65+ | 237 | 448.8 | 30.5 | 9.7 | 0.6 | * | 15.4 | 19.0 | 23.0 | 29.7 | 37.0 | 43.2 | 47.9 | *
| All | 3026 | 4538.3 | 41.8 | 28.2 | 0.5 | 12.2 | 17.2 | 20.0 | 25.6 | 33.6 | 47.1 | 73.0 | 97.0 | 156.0
All Seasons | All | 11888 | 17672.6 | 43.3 | 28.1 | 0.3 | 12.5 | 17.8 | 20.6 | 26.5 | 35.3 | 49.7 | 75.2 | 98.6 | 153.0

§ Does not include breast-fed children.

◆ Individual values nay not add to totals due to rounding.

* Value not reported due to insufficient number of observations.

Set B. Table 18 Total Water Intake (g/kg/day) of Females by Broad Age Category and Season (All Regions) ^§◆^

Season | Age (yr) | Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Season | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Spring | < 1 | 33 | 39.6 | 163.0 | 83.6 | 14.6 | * | * | * | 107.9 | 134.4 | 196.4 | * | * | *
| 1–10 | 536 | 716.2 | 73.7 | 30.7 | 1.3 | 26.0 | 32.8 | 38.6 | 50.8 | 69.4 | 92.1 | 115.8 | 132.0 | 167.6
| 11–19 | 675 | 876.6 | 35.2 | 13.6 | 0.5 | 9.1 | 16.6 | 20.6 | 26.0 | 33.5 | 41.9 | 50.7 | 61.3 | 78.0
| 20–64 | 2139 | 2833.2 | 32.2 | 12.0 | 0.3 | 11.2 | 15.9 | 18.5 | 23.7 | 30.4 | 38.7 | 47.9 | 54.8 | 68.2
| 65+ | 444 | 575.5 | 33.7 | 11.7 | 0.6 | 11.5 | 17.9 | 20.5 | 25.0 | 31.4 | 41.8 | 49.2 | 54.9 | 64.2
| All | 3827 | 5041.1 | 39.8 | 25.3 | 0.4 | 11.3 | 16.8 | 19.7 | 25.6 | 33.7 | 45.2 | 64.8 | 87.4 | 134.0
Sumner | < 1 | 44 | 58.4 | 172.3 | 64.3 | 9.7 | * | * | 101.4 | 126.3 | 160.1 | 203.0 | 243.7 | * | *
| 1–10 | 666 | 788.8 | 77.3 | 31.7 | 1.2 | 28.7 | 37.0 | 42.2 | 53.7 | 71.8 | 95.1 | 118.8 | 140.3 | 175.5
| 11–19 | 714 | 871.8 | 36.7 | 14.6 | 0.5 | 11.0 | 16.3 | 19.8 | 26.2 | 34.4 | 45.5 | 56.0 | 62.5 | 76.1
| 20–64 | 1375 | 3250.3 | 34.0 | 12.9 | 0.3 | 13.1 | 16.7 | 19.8 | 24.9 | 31.8 | 40.8 | 51.1 | 58.3 | 71.8
| 65+ | 328 | 620.9 | 34.7 | 11.9 | 0.7 | * | 18.2 | 20.8 | 26.1 | 33.0 | 41.2 | 51.7 | 58.2 | *
| All | 3127 | 5590.2 | 42.0 | 27.0 | 0.5 | 13.2 | 17.6 | 20.8 | 26.5 | 35.0 | 48.4 | 68.4 | 92.4 | 148.2
Fall | < 1 | 61 | 59.3 | 191.4 | 73.1 | 9.4 | * | * | 120.1 | 145.3 | 175.2 | 219.2 | 264.2 | * | *
| 1–10 | 779 | 812.2 | 74.2 | 31.4 | 1.1 | 26.5 | 35.2 | 40.7 | 52.0 | 68.1 | 90.3 | 114.6 | 138.4 | 180.9
| 11–19 | 808 | 883.5 | 34.9 | 13.5 | 0.5 | 11.3 | 17.0 | 19.9 | 25.2 | 32.5 | 42.5 | 52.8 | 61.4 | 77.2
| 20–64 | 1661 | 3358.8 | 32.8 | 12.7 | 0.3 | 11.5 | 16.1 | 19.1 | 24.3 | 30.7 | 38.9 | 49.2 | 56.5 | 74.2
| 65+ | 413 | 649.2 | 31.6 | 11.3 | 0.6 | 11.2 | 15.4 | 19.0 | 23.5 | 30.1 | 38.2 | 47.0 | 53.4 | 63.9
| All | 3722 | 5763.0 | 40.5 | 27.8 | 0.5 | 11.7 | 16.7 | 20.0 | 25.5 | 33.5 | 45.7 | 66.6 | 88.7 | 153.3
Winter | < 1 | 65 | 67.6 | 162.9 | 63.7 | 7.9 | * | * | 98.5 | 117.3 | 152.5 | 207.6 | 240.1 | * | *
| 1–10 | 770 | 813.1 | 71.6 | 32.1 | 1.2 | 24.6 | 33.7 | 39.3 | 49.1 | 64.9 | 86.6 | 111.5 | 134.4 | 182.2
| 11–19 | 760 | 829.7 | 35.3 | 13.8 | 0.5 | 11.5 | 16.3 | 19.9 | 25.8 | 33.3 | 43.2 | 54.3 | 58.5 | 73.8
| 20–64 | 1533 | 3134.7 | 32.5 | 12.4 | 0.3 | 10.4 | 15.5 | 18.4 | 23.5 | 31.1 | 39.2 | 47.8 | 55.9 | 71.6
| 65+ | 389 | 598.3 | 31.4 | 11.2 | 0.6 | 10.0 | 16.6 | 18.3 | 23.4 | 30.1 | 38.2 | 46.0 | 52.8 | 62.9
| All | 3517 | 5443.4 | 40.3 | 26.8 | 0.5 | 10.9 | 16.4 | 19.4 | 25.2 | 33.9 | 45.5 | 65.3 | 86.8 | 152.7
All Seasons | All | 14193 | 21837.6 | 40.7 | 26.8 | 0.2 | 11.8 | 16.8 | 20.0 | 25.7 | 34.0 | 46.2 | 66.4 | 88.9 | 148.0

§ Does not include pregnant women, lactating women, or breast-fed children.

◆ Individual values may not add to totals due to rounding.

* Value not reported due to insufficient number of observations.

### C TOTAL WATER INTAKE (g/kcal/day)

Set C. Table 19 Total Water Intake (g/kcal/day) by Broad Age Category and Sex (All Regions, All Seasons) ^§◆^

Sex | Age (yr) | Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Sex | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Both Sexes | < 1 | 403 | 444.3 | 1.5 | 0.5 | 0.0 | 0.8 | 1.0 | 1.1 | 1.3 | 1.5 | 1.7 | 1.9 | 2.0 | 3.5
| 1–10 | 5605 | 6354.1 | 1.0 | 0.3 | 0.0 | 0.5 | 0.6 | 0.7 | 0.8 | 1.0 | 1.2 | 1.4 | 1.5 | 2.0
| 11–19 | 5801 | 6824.9 | 1.0 | 0.4 | 0.0 | 0.5 | 0.6 | 0.7 | 0.8 | 0.9 | 1.1 | 1.4 | 1.6 | 2.4
| 20–64 | 11731 | 21744.9 | 1.3 | 0.7 | 0.0 | 0.5 | 0.7 | 0.8 | 0.9 | 1.2 | 1.5 | 2.0 | 2.4 | 3.6
| 65+ | 2541 | 4142.0 | 1.5 | 0.6 | 0.0 | 0.7 | 0.8 | 0.9 | 1.1 | 1.3 | 1.7 | 2.1 | 2.4 | 3.3
| All | 26081 | 39510.2 | 1.2 | 0.6 | 0.0 | 0.5 | 0.7 | 0.7 | 0.9 | 1.1 | 1.4 | 1.8 | 2.2 | 3.3
Males | < 1 | 200 | 219.4 | 1.5 | 0.3 | 0.0 | * | 1.1 | 1.1 | 1.3 | 1.5 | 1.7 | 1.9 | 2.0 | *
| 1–10 | 2854 | 3223.8 | 1.0 | 0.3 | 0.0 | 0.5 | 0.6 | 0.7 | 0.8 | 1.0 | 1.2 | 1.4 | 1.5 | 2.0
| 11–19 | 2844 | 3363.2 | 1.0 | 0.3 | 0.0 | 0.5 | 0.6 | 0.6 | 0.8 | 0.9 | 1.1 | 1.3 | 1.5 | 2.0
| 20–64 | 5023 | 9168.1 | 1.1 | 0.4 | 0.0 | 0.5 | 0.6 | 0.7 | 0.9 | 1.1 | 1.3 | 1.6 | 1.9 | 2.5
| 65+ | 967 | 1698.1 | 1.3 | 0.5 | 0.0 | 0.6 | 0.8 | 0.9 | 1.0 | 1.2 | 1.5 | 1.9 | 2.2 | 2.9
| All | 11888 | 17672.6 | 1.1 | 0.4 | 0.0 | 0.5 | 0.6 | 0.7 | 0.8 | 1.0 | 1.3 | 1.6 | 1.8 | 2.5
Females | < 1 | 203 | 225.0 | 1.6 | 0.6 | 0.0 | * | 1.0 | 1.1 | 1.3 | 1.5 | 1.7 | 1.9 | 2.1 | *
| 1–10 | 2751 | 3130.2 | 1.0 | 0.3 | 0.0 | 0.5 | 0.6 | 0.7 | 0.8 | 1.0 | 1.1 | 1.4 | 1.5 | 2.0
| 11–19 | 2957 | 3461.7 | 1.1 | 0.4 | 0.0 | 0.5 | 0.6 | 0.7 | 0.8 | 1.0 | 1.2 | 1.5 | 1.8 | 2.6
| 20–64 | 6708 | 12576.8 | 1.4 | 0.9 | 0.0 | 0.6 | 0.7 | 0.8 | 1.0 | 1.3 | 1.7 | 2.2 | 2.6 | 4.1
| 65+ | 1574 | 2443.9 | 1.5 | 0.6 | 0.0 | 0.7 | 0.8 | 1.0 | 1.1 | 1.4 | 1.8 | 2.3 | 2.6 | 3.6
| All | 14193 | 21837.6 | 1.3 | 0.7 | 0.0 | 0.5 | 0.7 | 0.8 | 0.9 | 1.2 | 1.6 | 2.0 | 2.4 | 3.8

§ Does not include pregnant women, lactating women, or breast-fed children.

◆ Individual values may not add to totals due to rounding.

* Value not reported due to insufficient number of observations.

0.0 Less than 0.05 g/kcal/day.

Set C. Table 20 Total Water Intake (g/kcal/day) by Fine Age Category and Sex (All Regions, All Seasons) ^§◆^

Sex | Age (yr) | Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Sex | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Both Sexes | < 0.5 | 182 | 201.2 | 1.5 | 0.5 | 0.0 | * | 1.1 | 1.2 | 1.3 | 1.5 | 1.7 | 1.9 | 2.0 | *
| 0.5–0.9 | 221 | 243.2 | 1.5 | 0.4 | 0.0 | * | 1.0 | 1.1 | 1.3 | 1.5 | 1.7 | 1.9 | 2.1 | *
| 1– 3 | 1498 | 1687.7 | 1.1 | 0.3 | 0.0 | 0.6 | 0.7 | 0.7 | 0.9 | 1.0 | 1.3 | 1.5 | 1.7 | 2.3
| 4– 6 | 1702 | 1923.9 | 1.0 | 0.3 | 0.0 | 0.5 | 0.6 | 0.7 | 0.8 | 1.0 | 1.2 | 1.4 | 1.5 | 1.9
| 7–10 | 2405 | 2742.4 | 0.9 | 0.3 | 0.0 | 0.5 | 0.6 | 0.6 | 0.8 | 0.9 | 1.1 | 1.3 | 1.4 | 1.7
| 11–14 | 2803 | 3146.9 | 1.0 | 0.3 | 0.0 | 0.5 | 0.6 | 0.7 | 0.8 | 0.9 | 1.1 | 1.3 | 1.5 | 2.2
| 15–19 | 2998 | 3677.9 | 1.0 | 0.4 | 0.0 | 0.5 | 0.6 | 0.7 | 0.8 | 1.0 | 1.2 | 1.5 | 1.7 | 2.5
| 20–44 | 7171 | 13444.5 | 1.3 | 0.8 | 0.0 | 0.5 | 0.7 | 0.7 | 0.9 | 1.1 | 1.4 | 1.9 | 2.3 | 3.4
| 45–64 | 4560 | 8300.4 | 1.4 | 0.6 | 0.0 | 0.6 | 0.8 | 0.9 | 1.0 | 1.3 | 1.6 | 2.1 | 2.5 | 3.7
| 65–74 | 1663 | 2740.2 | 1.5 | 0.6 | 0.0 | 0.7 | 0.8 | 0.9 | 1.1 | 1.4 | 1.7 | 2.2 | 2.5 | 3.7
| >75 | 878 | 1401.8 | 1.4 | 0.5 | 0.0 | 0.6 | 0.8 | 0.9 | 1.1 | 1.3 | 1.6 | 2.0 | 2.3 | 3.0
| All | 26081 | 39510.2 | 1.2 | 0.6 | 0.0 | 0.5 | 0.7 | 0.7 | 0.9 | 1.1 | 1.4 | 1.8 | 2.2 | 3.3
Males | < 0.5 | 87 | 96.4 | 1.5 | 0.3 | 0.0 | * | 1.1 | 1.2 | 1.3 | 1.5 | 1.7 | 1.8 | 2.0 | *
| 0.5–0.9 | 113 | 122.9 | 1.5 | 0.3 | 0.0 | * | 1.0 | 1.1 | 1.3 | 1.5 | 1.7 | 1.9 | 2.0 | *
| 1– 3 | 775 | 879.6 | 1.1 | 0.4 | 0.0 | 0.6 | 0.7 | 0.7 | 0.9 | 1.0 | 1.3 | 1.5 | 1.8 | 2.5
| 4– 6 | 883 | 991.4 | 1.0 | 0.3 | 0.0 | 0.5 | 0.6 | 0.7 | 0.8 | 1.0 | 1.2 | 1.4 | 1.5 | 1.9
| 7–10 | 1196 | 1352.9 | 0.9 | 0.3 | 0.0 | 0.5 | 0.6 | 0.6 | 0.7 | 0.9 | 1.1 | 1.3 | 1.4 | 1.7
| 11–14 | 1395 | 1571.8 | 0.9 | 0.3 | 0.0 | 0.5 | 0.6 | 0.6 | 0.7 | 0.9 | 1.1 | 1.3 | 1.4 | 1.9
| 15–19 | 1449 | 1791.4 | 1.0 | 0.3 | 0.0 | 0.5 | 0.6 | 0.6 | 0.8 | 0.9 | 1.1 | 1.3 | 1.5 | 2.1
| 20–44 | 3146 | 5702.7 | 1.1 | 0.4 | 0.0 | 0.5 | 0.6 | 0.7 | 0.8 | 1.0 | 1.3 | 1.6 | 1.8 | 2.5
| 45–64 | 1877 | 3465.4 | 1.2 | 0.4 | 0.0 | 0.6 | 0.7 | 0.8 | 0.9 | 1.2 | 1.4 | 1.7 | 2.0 | 2.6
| 65–74 | 656 | 1172.3 | 1.3 | 0.5 | 0.0 | 0.6 | 0.8 | 0.9 | 1.0 | 1.2 | 1.5 | 1.9 | 2.2 | 2.9
| 75+ | 311 | 525.8 | 1.3 | 0.4 | 0.0 | * | 0.8 | 0.9 | 1.0 | 1.2 | 1.5 | 1.9 | 2.2 | 2.9
| All | 11888 | 17672.6 | 1.1 | 0.4 | 0.0 | 0.5 | 0.6 | 0.7 | 0.8 | 1.0 | 1.3 | 1.6 | 1.8 | 2.5
Females | < 0.5 | 95 | 104.7 | 1.6 | 0.7 | 0.1 | * | 1.1 | 1.2 | 1.3 | 1.5 | 1.7 | 1.9 | 2.0 | *
| 0.5–0.9 | 108 | 120.2 | 1.5 | 0.5 | 0.0 | * | 1.0 | 1.1 | 1.3 | 1.5 | 1.7 | 2.0 | 2.1 | *
| 1– 3 | 723 | 808.2 | 1.1 | 0.3 | 0.0 | 0.6 | 0.7 | 0.7 | 0.9 | 1.0 | 1.3 | 1.5 | 1.7 | 2.3
| 4– 6 | 819 | 932.5 | 1.0 | 0.3 | 0.0 | 0.5 | 0.6 | 0.7 | 0.8 | 1.0 | 1.1 | 1.4 | 1.6 | 1.8
| 7–10 | 1209 | 1389.5 | 0.9 | 0.3 | 0.0 | 0.5 | 0.6 | 0.7 | 0.8 | 0.9 | 1.1 | 1.3 | 1.4 | 1.7
| 11–14 | 1408 | 1575.1 | 1.0 | 0.4 | 0.0 | 0.5 | 0.6 | 0.7 | 0.8 | 0.9 | 1.1 | 1.4 | 1.6 | 2.4
| 15–19 | 1549 | 1886.5 | 1.1 | 0.5 | 0.0 | 0.5 | 0.6 | 0.7 | 0.8 | 1.0 | 1.2 | 1.6 | 1.9 | 3.0
| 20–44 | 4025 | 7741.7 | 1.4 | 0.9 | 0.0 | 0.6 | 0.7 | 0.8 | 1.0 | 1.2 | 1.6 | 2.1 | 2.5 | 4.1
| 45–64 | 2683 | 4835.1 | 1.6 | 0.7 | 0.0 | 0.6 | 0.8 | 0.9 | 1.1 | 1.4 | 1.8 | 2.3 | 2.8 | 4.2
| 65–74 | 1007 | 1567.9 | 1.6 | 0.7 | 0.0 | 0.7 | 0.8 | 1.0 | 1.2 | 1.4 | 1.9 | 2.3 | 2.7 | 3.8
| 75+ | 567 | 876.0 | 1.5 | 0.5 | 0.0 | 0.7 | 0.8 | 0.9 | 1.1 | 1.4 | 1.7 | 2.0 | 2.4 | 3.0
| All | 14193 | 21837.6 | 1.3 | 0.7 | 0.0 | 0.5 | 0.7 | 0.8 | 0.9 | 1.2 | 1.6 | 2.0 | 2.4 | 3.8

§ Does not include pregnant women, lactating women, or breast-fed children.

◆ Individual values may not add to totals due to rounding.

* Value not reported due to insufficient number of observations.

0.0 Less than 0.05 g/kcal/day.

Set C. Table 21 Total Water Intake (g/kcal/day) of Pregnant Women, Lactating Women, and Breast-fed Children (All Regions, All Seasons)

| Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
| Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 5 | 10 | 25 | 50 | 75 | 90 | 95
Pregnant women | 188 | 327.5 | 1.3 | 0.5 | 0.0 | 0.7 | 0.8 | 0.9 | 1.2 | 1.5 | 1.9 | 2.2
Lactating women | 77 | 151.2 | 1.3 | 0.4 | 0.0 | 0.7 | 0.8 | 1.0 | 1.2 | 1.5 | 1.8 | 2.1
Breast-fed children^§^
Both sexes
All ages | 100 | 121.0 | 1.3 | 1.5 | 0.2 | 0.0 | 0.0 | 0.2 | 1.1 | 1.6 | 2.6 | 3.6
< 0.5 yr | 62 | 74.4 | 1.0 | 1.2 | 0.2 | * | 0.0 | 0.0 | 1.1 | 1.6 | 2.4 | *
≥ 0.5 yr | 38 | 46.6 | 1.7 | 1.8 | 0.3 | * | 0.7 | 1.0 | 1.2 | 1.7 | 2.9 | *
Males
All ages | 42 | 49.4 | 1.1 | 1.4 | 0.2 | * | 0.0 | 0.2 | 1.0 | 1.6 | 1.9 | *
< 0.5 yr | 28 | 34.0 | 0.9 | 0.9 | 0.2 | * | * | 0.0 | 0.7 | 1.6 | * | *
≥ 0.5 yr | 14 | 15.5 | * | * | * | * | * | 0.9 | 1.0 | 1.6 | * | *
Females
All ages | 58 | 71.6 | 1.4 | 1.5 | 0.2 | * | 0.0 | 0.7 | 1.2 | 1.8 | 2.9 | *
< 0.5 yr | 34 | 40.5 | 1.1 | 1.4 | 0.2 | * | * | 0.0 | 1.1 | 1.8 | * | *
≥ 0.5 yr | 24 | 31.1 | * | * | * | * | * | 1.0 | 1.3 | 1.8 | * | *

§ Total water intake of breast-fed children does not include the contribution of breast milk.

* Value not reported due to insufficient number of observations.

0.0 Less than 0.05 g/kcal/day.

Set C. Table 22 Total Water Intake (g/kcal/day) of Both Sexes by Broad Age Category and Geographic Region (All Seasons) ^§◆^

Region | Age (yr) | Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Region | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Northeast | < 1 | 84 | 95.7 | 1.5 | 0.7 | 0.1 | * | 0.9 | 1.1 | 1.2 | 1.4 | 1.5 | 1.8 | 2.1 | *
| 1–10 | 1323 | 1519.2 | 0.9 | 0.3 | 0.0 | .0.5 | 0.6 | 0.6 | 0.7 | 0.9 | 1.0 | 1.2 | 1.4 | 2.0
| 11–19 | 1324 | 1565.0 | 0.9 | 0.4 | 0.0 | .0.4 | 0.5 | 0.6 | 0.7 | 0.8 | 1.0 | 1.3 | 1.5 | 2.4
| 20–64 | 2883 | 5548.0 | 1.2 | 0.6 | 0.0 | 0.5 | 0.6 | 0.7 | 0.9 | 1.1 | 1.4 | 1.8 | 2.1 | 3.0
| 65+ | 584 | 959.4 | 1.3 | 0.5 | 0.0 | 0.6 | 0.8 | 0.8 | 1.0 | 1.2 | 1.5 | 1.9 | 2.2 | 3.4
| All | 6198 | 9687.3 | 1.1 | 0.5 | 0.0 | 0.5 | 0.6 | 0.7 | 0.8 | 1.0 | 1.3 | 1.7 | 2.0 | 2.8
Midwest | < 1 | 101 | 114.5 | 1.5 | 0.3 | 0.0 | * | 1.0 | 1.1 | 1.3 | 1.5 | 1.7 | 1.9 | 2.0 | *
| 1–10 | 1505 | 1700.8 | 1.0 | 0.3 | 0.0 | 0.5 | 0.6 | 0.7 | 0.8 | 1.0 | 1.1 | 1.3 | 1.5 | 1.8
| 11–19 | 1611 | 1908.0 | 1.0 | 0.4 | 0.0 | 0.5 | 0.6 | 0.7 | 0.8 | 0.9 | 1.2 | 1.4 | 1.6 | 2.2
| 20–64 | 2972 | 5593.4 | 1.3 | 0.6 | 0.0 | 0.5 | 0.7 | 0.8 | 0.9 | 1.2 | 1.5 | 2.0 | 2.3 | 3.5
| 65+ | 604 | 1037.5 | 1.5 | 0.5 | 0.0 | 0.7 | 0.9 | 1.0 | 1.1 | 1.3 | 1.7 | 2.1 | 2.4 | 2.9
| All | 6793 | 10354.2 | 1.2 | 0.5 | 0.0 | 0.5 | 0.7 | 0.7 | 0.9 | 1.1 | 1.4 | 1.8 | 2.1 | 3.2
South | < 1 | 150 | 146.3 | 1.6 | 0.5 | 0.0 | * | 1.1 | 1.2 | 1.3 | 1.5 | 1.7 | 2.0 | 2.1 | *
| 1–10 | 1928 | 2006.8 | 1.1 | 0.3 | 0.0 | 0.5 | 0.6 | 0.7 | 0.8 | 1.0 | 1.2 | 1.5 | 1.7 | 2.1
| 11–19 | 1982 | 2154.1 | 1.1 | 0.4 | 0.0 | 0.5 | 0.6 | 0.7 | 0.8 | 1.0 | 1.2 | 1.5 | 1.7 | 2.4
| 20–64 | 3980 | 6642.8 | 1.4 | 0.6 | 0.0 | 0.6 | 0.7 | 0.8 | 1.0 | 1.3 | 1.6 | 2.1 | 2.5 | 3.8
| 65+ | 970 | 1448.1 | 1.6 | 0.7 | 0.0 | 0.6 | 0.8 | 0.9 | 1.1 | 1.4 | 1.8 | 2.3 | 2.6 | 4.0
| All | 9010 | 12398.1 | 1.3 | 0.6 | 0.0 | 0.6 | 0.7 | 0.8 | 0.9 | 1.2 | 1.5 | 2.0 | 2.3 | 3.4
West | < 1 | 68 | 87.7 | 1.6 | 0.4 | 0.0 | * | * | 1.2 | 1.3 | 1.6 | 1.7 | 1.9 | * | *
| 1–10 | 849 | 1127.2 | 1.0 | 0.3 | 0.0 | 0.5 | 0.6 | 0.7 | 0.8 | 1.0 | 1.2 | 1.4 | 1.6 | 2.0
| 11–19 | 884 | 1197.8 | 1.0 | 0.4 | 0.0 | 0.5 | 0.6 | 0.7 | 0.8 | 0.9 | 1.2 | 1.4 | 1.6 | 2.1
| 20–64 | 1896 | 3960.7 | 1.4 | 1.1 | 0.0 | 0.5 | 0.7 | 0.8 | 0.9 | 1.2 | 1.6 | 2.1 | 2.6 | 4.3
| 65+ | 383 | 697.0 | 1.5 | 0.5 | 0.0 | 0.7 | 0.8 | 0.9 | 1.1 | 1.3 | 1.7 | 2.1 | 2.4 | 3.1
| All | 4080 | 7070.4 | 1.3 | 0.9 | 0.0 | 0.5 | 0.7 | 0.7 | 0.9 | 1.1 | 1.5 | 1.9 | 2.3 | 3.5
All Regions | All | 26081 | 39510.2 | 1.2 | 0.6 | 0.0 | 0.5 | 0.7 | 0.7 | 0.9 | 1.1 | 1.4 | 1.8 | 2.2 | 3.3

§ Does not include pregnant women, lactating women, or breast-fed children.

◆ Individual values may not add to totals due to rounding.

* Value not reported due to insufficient number of observations.

0.0 Less than 0.05 g/kcal/day.

Set C. Table 23 Total Water Intake (g/kcal/day) of Both Sexes by Broad Age Category and Season (All Regions) ^§◆^

Season | Age (yr) | Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Season | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Spring | < 1 | 63 | 78.9 | 1.5 | 0.3 | 0.0 | * | * | 1.1 | 1.3 | 1.4 | 1.7 | 2.0 | * | *
| 1–10 | 1117 | 1511.9 | 1.0 | 0.3 | 0.0 | 0.5 | 0.6 | 0.7 | 0.8 | 1.0 | 1.2 | 1.4 | 1.6 | 1.9
| 11–19 | 1332 | 1760.4 | 1.0 | 0.4 | 0.0 | 0.5 | 0.6 | 0.7 | 0.8 | 0.9 | 1.1 | 1.4 | 1.6 | 2.3
| 20–64 | 3997 | 5258.9 | 1.3 | 0.6 | 0.0 | 0.5 | 0.7 | 0.8 | 0.9 | 1.2 | 1.5 | 2.0 | 2.3 | 3.5
| 65+ | 770 | 996.5 | 1.5 | 0.5 | 0.0 | 0.6 | 0.8 | 0.9 | 1.1 | 1.4 | 1.7 | 2.1 | 2.4 | 3.1
| All | 7279 | 9606.6 | 1.2 | 0.6 | 0.0 | 0.5 | 0.7 | 0.7 | 0.9 | 1.1 | 1.4 | 1.8 | 2.2 | 3.2
Summer | < 1 | 107 | 130.1 | 1.5 | 0.6 | 0.1 | * | 0.9 | 1.1 | 1.3 | 1.5 | 1.7 | 2.0 | 2.2 | *
| 1–10 | 1321 | 1568.1 | 1.0 | 0.3 | 0.0 | 0.6 | 0.6 | 0.7 | 0.8 | 1.0 | 1.2 | 1.4 | 1.6 | 2.0
| 11–19 | 1356 | 1672.0 | 1.1 | 0.4 | 0.0 | 0.5 | 0.6 | 0.7 | 0.8 | 1.0 | 1.2 | 1.5 | 1.8 | 2.6
| 20–64 | 2327 | 5534.3 | 1.4 | 0.9 | 0.0 | 0.6 | 0.7 | 0.8 | 1.0 | 1.2 | 1.6 | 2.0 | 2.5 | 3.7
| 65+ | 513 | 1025.1 | 1.6 | 0.7 | 0.0 | 0.7 | 0.9 | 1.0 | 1.1 | 1.4 | 1.8 | 2.3 | 2.6 | 4.4
| All | 5624 | 9929.6 | 1.3 | 0.8 | 0.0 | 0.5 | 0.7 | 0.8 | 0.9 | 1.2 | 1.5 | 1.9 | 2.3 | 3.3
Pall | < 1 | 108 | 109.7 | 1.5 | 0.4 | 0.0 | * | 1.1 | 1.1 | 1.3 | 1.5 | 1.7 | 1.8 | 2.0 | *
| 1–10 | 1619 | 1648.4 | 1.0 | 0.3 | 0.0 | 0.5 | 0.6 | 0.7 | 0.8 | 0.9 | 1.1 | 1.3 | 1.5 | 2.0
| 11–19 | 1584 | 1717.0 | 1.0 | 0.3 | 0.0 | 0.5 | 0.6 | 0.6 | 0.7 | 0.9 | 1.1 | 1.3 | 1.5 | 2.1
| 20–64 | 2692 | 5444.0 | 1.3 | 0.6 | 0.0 | 0.5 | 0.7 | 0.8 | 0.9 | 1.2 | 1.5 | 2.0 | 2.4 | 3.7
| 65+ | 632 | 1073.3 | 1.4 | 0.6 | 0.0 | 0.7 | 0.8 | 0.9 | 1.1 | 1.3 | 1.6 | 2.0 | 2.4 | 3.4
| All | 6635 | 9992.4 | 1.2 | 0.6 | 0.0 | 0.5 | 0.6 | 0.7 | 0.9 | 1.1 | 1.4 | 1.8 | 2.2 | 3.3
Winter | < 1 | 125 | 125.7 | 1.5 | 0.5 | 0.0 | * | 1.1 | 1.1 | 1.3 | 1.5 | 1.7 | 1.9 | 2.0 | *
| 1–10 | 1548 | 1625.7 | 1.0 | 0.3 | 0.0 | 0.5 | 0.6 | 0.7 | 0.8 | 0.9 | 1.1 | 1.3 | 1.5 | 2.0
| 11–19 | 1529 | 1675.6 | 1.0 | 0.4 | 0.0 | 0.5 | 0.6 | 0.6 | 0.8 | 0.9 | 1.1 | 1.3 | 1.6 | 2.4
| 20–64 | 2715 | 5507.7 | 1.3 | 0.7 | 0.0 | 0.5 | 0.7 | 0.8 | 0.9 | 1.2 | 1.5 | 1.9 | 2.3 | 3.5
| 65+ | 626 | 1047.1 | 1.4 | 0.5 | 0.0 | 0.6 | 0.8 | 0.9 | 1.0 | 1.3 | 1.6 | 2.0 | 2.3 | 3.3
| All | 6543 | 9981.8 | 1.2 | 0.6 | 0.0 | 0.5 | 0.6 | 0.7 | 0.9 | 1.1 | 1.4 | 1.8 | 2.1 | 3.3
All Seasons | All | 26081 | 39510.2 | 1.2 | 0.6 | 0.0 | 0.5 | 0.7 | 0.7 | 0.9 | 1.1 | 1.4 | 1.8 | 2.2 | 3.3

§ Does not include pregnant women, lactating women, or breast-fed children.

◆ Individual values may not add to totals due to rounding.

* Value not reported due to insufficient number of observations.

0.0 Less than 0.05 g/kcal/day.

### D TAPWATER INTAKE (g/day)

Set D. Table 24 Tapwater Intake (g/day) by Broad Age Category and Sex (All Regions, All Seasons)^§◆¶^

Sex | Age (yr) | Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Sex | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Both Sexes | < 1 | 403 | 444.3 | 302 | 258 | 13 | 0 | 0 | 0 | 113 | 240 | 424 | 649 | 775 | 1102
| 1–10 | 5605 | 6354.1 | 736 | 410 | 5 | 56 | 192 | 286 | 442 | 665 | 960 | 1294 | 1516 | 1954
| 11–19 | 5801 | 6824.9 | 965 | 562 | 7 | 67 | 240 | 353 | 574 | 867 | 1246 | 1701 | 2026 | 2748
| 20–64 | 11731 | 21744.9 | 1366 | 728 | 7 | 148 | 416 | 559 | 870 | 1252 | 1737 | 2268 | 2707 | 3780
| 65+ | 2541 | 4142.0 | 1459 | 643 | 13 | 299 | 598 | 751 | 1019 | 1367 | 1806 | 2287 | 2636 | 3338
| All | 26081 | 39510.2 | 1193 | 702 | 4 | 80 | 286 | 423 | 690 | 1081 | 1561 | 2092 | 2477 | 3415
Males | < 1 | 200 | 219.4 | 290 | 244 | 17 | * | 0 | 0 | 94 | 240 | 400 | 634 | 764 | *
| 1–10 | 2854 | 3223.8 | 761 | 425 | 8 | 56 | 209 | 294 | 456 | 687 | 995 | 1340 | 1555 | 2017
| 11–19 | 2844 | 3363.2 | 1050 | 605 | 11 | 80 | 279 | 381 | 616 | 942 | 1364 | 1856 | 2179 | 2967
| 20–64 | 5023 | 9168.1 | 1460 | 798 | 11 | 160 | 431 | 582 | 918 | 1339 | 1841 | 2485 | 2949 | 4083
| 65+ | 967 | 1698.1 | 1570 | 704 | 23 | 381 | 616 | 799 | 1115 | 1448 | 1952 | 2460 | 2790 | 3712
| All | 11888 | 17672.6 | 1250 | 759 | 7 | 80 | 291 | 426 | 706 | 1123 | 1634 | 2205 | 2673 | 3760
Females | < 1 | 203 | 225.0 | 315 | 271 | 19 | * | 0 | 0 | 115 | 240 | 461 | 707 | 775 | *
| 1–10 | 2751 | 3130.2 | 711 | 394 | 8 | 58 | 184 | 278 | 433 | 639 | 930 | 1237 | 1462 | 1877
| 11–19 | 2957 | 3461.7 | 882 | 503 | 9 | 59 | 217 | 326 | 534 | 799 | 1147 | 1540 | 1825 | 2424
| 20–64 | 6708 | 12576.8 | 1297 | 664 | 8 | 141 | 409 | 551 | 836 | 1207 | 1655 | 2147 | 2491 | 3359
| 65+ | 1574 | 2443.9 | 1382 | 584 | 15 | 260 | 588 | 732 | 964 | 1309 | 1687 | 2167 | 2472 | 3071
| All | 14193 | 21837.6 | 1147 | 648 | 5 | 80 | 281 | 421 | 676 | 1049 | 1505 | 1988 | 2316 | 3097

§ Does not include pregnant women, lactating women, or breast-fed children.

◆ Individual values may not add to totals due to rounding.

¶ Please see Discussion (Special Problem: Infants) (page 34) regarding limitations of Tapwater estimates for infants <1 year.

* Value not reported due to insufficient number of observations.

0 Less than 0.5 g/day.

Set D. Table 25 Tapwater Intake (g/day) by Fine Age Category and Sex (All Regions, All Seasons)^§◆¶^

Sex | Age (yr) | Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Sex | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Both Sexes | < 0.5 | 182 | 201.2 | 272 | 247 | 18 | * | 0 | 0 | 80 | 240 | 332 | 640 | 800 | *
| 0.5–0.9 | 221 | 243.2 | 328 | 265 | 18 | * | 0 | 0 | 117 | 268 | 480 | 688 | 764 | *
| 1– 3 | 1498 | 1687.7 | 646 | 390 | 10 | 33 | 169 | 240 | 374 | 567 | 820 | 1162 | 1419 | 1899
| 4– 6 | 1702 | 1923.9 | 742 | 406 | 10 | 68 | 204 | 303 | 459 | 660 | 972 | 1302 | 1520 | 1932
| 7–10 | 2405 | 2742.4 | 787 | 417 | 9 | 68 | 241 | 318 | 484 | 731 | 1016 | 1338 | 1556 | 1998
| 11–14 | 2803 | 3146.9 | 925 | 521 | 10 | 76 | 244 | 360 | 561 | 838 | 1196 | 1621 | 1924 | 2503
| 15–19 | 2998 | 3677.9 | 999 | 593 | 11 | 55 | 239 | 348 | 587 | 897 | 1294 | 1763 | 2134 | 2871
| 20–44 | 7171 | 13444.5 | 1255 | 709 | 8 | 105 | 337 | 483 | 766 | 1144 | 1610 | 2121 | 2559 | 3634
| 45–64 | 4560 | 8300.4 | 1546 | 723 | 11 | 335 | 591 | 745 | 1057 | 1439 | 1898 | 2451 | 2870 | 3994
| 65–74 | 1663 | 2740.2 | 1500 | 660 | 16 | 301 | 611 | 766 | 1044 | 1394 | 1873 | 2333 | 2693 | 3479
| 75+ | 878 | 1401.8 | 1381 | 600 | 20 | 279 | 568 | 728 | 961 | 1302 | 1706 | 2170 | 2476 | 3087
| All | 26081 | 39510.2 | 1193 | 702 | 4 | 80 | 286 | 423 | 690 | 1081 | 1561 | 2092 | 2477 | 3415
Males | < 0.5 | 87 | 96.4 | 250 | 232 | 25 | * | 0 | 0 | 68 | 240 | 320 | 569 | 757 | *
| 0.5–0.9 | 113 | 122.9 | 322 | 249 | 23 | * | 0 | 17 | 160 | 264 | 408 | 634 | 871 | *
| 1– 3 | 775 | 879.6 | 683 | 406 | 15 | 18 | 192 | 248 | 401 | 606 | 867 | 1228 | 1464 | 2061
| 4– 6 | 883 | 991.4 | 773 | 414 | 14 | 60 | 225 | 317 | 480 | 693 | 1033 | 1336 | 1530 | 1900
| 7–10 | 1196 | 1352.9 | 802 | 437 | 13 | 74 | 229 | 313 | 477 | 738 | 1046 | 1391 | 1609 | 2055
| 11–14 | 1395 | 1571.8 | 970 | 547 | 15 | 80 | 274 | 364 | 587 | 877 | 1243 | 1714 | 2019 | 2653
| 15–19 | 1449 | 1791.4 | 1120 | 644 | 17 | 86 | 286 | 403 | 659 | 1019 | 1451 | 1974 | 2283 | 3090
| 20–44 | 3146 | 5702.7 | 1354 | 788 | 14 | 105 | 342 | 505 | 809 | 1216 | 1740 | 2309 | 2837 | 4065
| 45–64 | 1877 | 3465.4 | 1633 | 783 | 18 | 338 | 599 | 759 | 1095 | 1510 | 2030 | 2650 | 3094 | 4213
| 65–74 | 656 | 1172.3 | 1594 | 719 | 28 | 314 | 633 | 808 | 1142 | 1457 | 1969 | 2502 | 2812 | *
| 75+ | 311 | 525.8 | 1517 | 667 | 38 | * | 570 | 744 | 1058 | 1443 | 1847 | 2332 | 2698 | *
| All | 11888 | 17672.6 | 1250 | 759 | 7 | 80 | 291 | 426 | 706 | 1123 | 1634 | 2205 | 2673 | 3760
Females | < 0.5 | 95 | 104.7 | 293 | 259 | 27 | * | 0 | 0 | 160 | 240 | 358 | 672 | 800 | *
| 0.5–0.9 | 108 | 120.2 | 333 | 281 | 27 | * | 0 | 0 | 113 | 278 | 500 | 712 | 759 | *
| 1– 3 | 723 | 808.2 | 606 | 368 | 14 | 42 | 157 | 215 | 345 | 532 | 783 | 1114 | 1339 | 1806
| 4– 6 | 819 | 932.5 | 709 | 395 | 14 | 68 | 184 | 291 | 441 | 622 | 930 | 1231 | 1491 | 1932
| 7–10 | 1209 | 1389.5 | 772 | 395 | 11 | 68 | 249 | 328 | 491 | 726 | 992 | 1299 | 1475 | 1888
| 11–14 | 1408 | 1575.1 | 881 | 490 | 13 | 69 | 234 | 355 | 543 | 797 | 1151 | 1531 | 1814 | 2382
| 15–19 | 1549 | 1886.5 | 883 | 513 | 13 | 43 | 194 | 316 | 530 | 800 | 1147 | 1565 | 1839 | 2452
| 20–44 | 4025 | 7741.7 | 1182 | 634 | 10 | 104 | 331 | 478 | 740 | 1089 | 1527 | 1996 | 2323 | 3132
| 45–64 | 2683 | 4835.1 | 1483 | 670 | 13 | 320 | 578 | 733 | 1038 | 1394 | 1823 | 2303 | 2668 | 3666
| 65–74 | 1007 | 1567.9 | 1429 | 603 | 19 | 295 | 596 | 739 | 1003 | 1360 | 1764 | 2247 | 2561 | 3082
| 75+ | 567 | 876.0 | 1300 | 540 | 23 | 162 | 568 | 712 | 931 | 1250 | 1588 | 1998 | 2242 | 2933
| All | 14193 | 21837.6 | 1147 | 648 | 5 | 80 | 281 | 421 | 676 | 1049 | 1505 | 1988 | 2316 | 3097

§ Does not include pregnant women, lactating women, or breast-fed children.

◆ Individual values may not add to totals due to rounding.

¶ Please see Discussion (Special Problem: Infants) (page 34) regarding limitations of Tapwater estimates for infants <1 year.

* Value not reported due to insufficient number of observations.

0 Less than 0.5 g/day.

Set D. Table 26 Tapwater Intake (g/day) of Pregnant Women, Lactating Women, and Breast-fed Children (All Regions, All Seasons) ^¶^

| Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
| Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 5 | 10 | 25 | 50 | 75 | 90 | 95
Pregnant women | 188 | 327.5 | 1189 | 699 | 51 | 274 | 419 | 713 | 1063 | 1501 | 2191 | 2424
Lactating women | 77 | 151.2 | 1310 | 591 | 67 | 430 | 612 | 855 | 1330 | 1693 | 1945 | 2191
Breast-fed children
Both sexes
All ages | 100 | 121.0 | 153 | 175 | 18 | 0 | 0 | 0 | 89 | 249 | 351 | 468
< 0.5 yr | 62 | 74.4 | 119 | 168 | 21 | * | 0 | 0 | 0 | 240 | 296 | *
≥ 0.5 yr | 38 | 46.6 | 208 | 174 | 28 | * | 0 | 70 | 240 | 296 | 445 | *
Males
All ages | 42 | 49.4 | 120 | 150 | 23 | * | 0 | 0 | 61 | 240 | 323 | *
< 0.5 yr | 28 | 34.0 | 83 | 137 | 26 | * | * | 0 | 0 | 94 | * | *
≥ 0.5 yr | 14 | 15.5 | * | * | * | * | * | 70 | 240 | 320 | * | *
Females
All ages | 58 | 71.6 | 176 | 188 | 25 | * | 0 | 0 | 160 | 260 | 400 | *
< 0.5 yr | 34 | 40.5 | 149 | 187 | 32 | * | * | 0 | 148 | 240 | * | *
≥ 0.5 yr | 24 | 31.1 | * | * | * | * | * | 80 | 167 | 296 | * | *

¶ Please see Discussion (Special Problem: Infants) (page 34) regarding limitations of Tapwater estimates for infants <1 year.

* Value not reported due to insufficient number of observations.

0 Less than 0.5 g/day.

Set D. Table 27 Tapwater Intake (g/day) of Both Sexes by Broad Age Category and Geographic Region (All Seasons) ^§◆¶^

Region | Age (yr) | Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Region | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Northeast | < 1 | 84 | 95.7 | 229 | 211 | 23 | * | 0 | 0 | 74 | 240 | 337 | 522 | 575 | *
| 1–10 | 1323 | 1519.2 | 568 | 350 | 10 | 18 | 108 | 191 | 328 | 511 | 732 | 1016 | 1231 | 1678
| 11–19 | 1324 | 1565.0 | 787 | 465 | 13 | 31 | 165 | 259 | 480 | 723 | 1005 | 1360 | 1677 | 2227
| 20–64 | 2883 | 5548.0 | 1162 | 592 | 11 | 148 | 371 | 499 | 759 | 1080 | 1471 | 1879 | 2188 | 3148
| 65+ | 584 | 959.4 | 1275 | 602 | 25 | 246 | 552 | 688 | 895 | 1181 | 1577 | 1969 | 2217 | 2989
| All | 6198 | 9687.3 | 1010 | 597 | 8 | 60 | 224 | 340 | 592 | 925 | 1328 | 1763 | 2074 | 2842
Midwest | < 1 | 101 | 114.5 | 300 | 237 | 24 | * | 0 | 0 | 158 | 240 | 421 | 634 | 757 | *
| 1–10 | 1505 | 1700.8 | 758 | 392 | 10 | 56 | 258 | 323 | 483 | 689 | 965 | 1315 | 1526 | 1991
| 11–19 | 1611 | 1908.0 | 950 | 550 | 14 | 63 | 243 | 357 | 561 | 855 | 1235 | 1657 | 1993 | 2622
| 20–64 | 2972 | 5593.4 | 1387 | 715 | 13 | 161 | 414 | 568 | 903 | 1290 | 1762 | 2250 | 2656 | 3684
| 65+ | 604 | 1037.5 | 1504 | 602 | 24 | 314 | 673 | 823 | 1113 | 1440 | 1818 | 2287 | 2547 | 3456
| All | 6793 | 10354.2 | 1203 | 689 | 8 | 95 | 296 | 434 | 705 | 1102 | 1601 | 2062 | 2432 | 3372
South | < 1 | 150 | 146.3 | 317 | 280 | 23 | * | 0 | 0 | 80 | 240 | 472 | 728 | 832 | *
| 1–10 | 1928 | 2006.8 | 818 | 426 | 10 | 58 | 264 | 337 | 512 | 750 | 1049 | 1382 | 1615 | 2059
| 11–19 | 1982 | 2154.1 | 1092 | 589 | 13 | 109 | 328 | 455 | 672 | 991 | 1404 | 1865 | 2170 | 2888
| 20–64 | 3980 | 6642.8 | 1466 | 753 | 12 | 160 | 484 | 628 | 945 | 1362 | 1841 | 2433 | 2837 | 4008
| 65+ | 970 | 1448.1 | 1510 | 679 | 22 | 318 | 596 | 747 | 1038 | 1399 | 1933 | 2400 | 2766 | 3435
| All | 9010 | 12398.1 | 1288 | 724 | 8 | 93 | 348 | 488 | 773 | 1170 | 1662 | 2238 | 2648 | 3597
West | < 1 | 68 | 87.7 | 362 | 277 | 34 | * | * | 0 | 240 | 276 | 517 | 754 | * | *
| 1–10 | 849 | 1127.2 | 782 | 420 | 14 | 107 | 234 | 303 | 465 | 710 | 1042 | 1367 | 1564 | 1951
| 11–19 | 884 | 1197.8 | 992 | 582 | 20 | 70 | 247 | 346 | 574 | 902 | 1299 | 1764 | 2143 | 2780
| 20–64 | 1896 | 3960.7 | 1452 | 814 | 19 | 115 | 400 | 547 | 888 | 1322 | 1901 | 2489 | 2986 | 4152
| 65+ | 383 | 697.0 | 1543 | 629 | 32 | 299 | 712 | 840 | 1150 | 1433 | 1881 | 2490 | 2794 | 3241
| All | 4080 | 7070.4 | 1263 | 764 | 12 | 88 | 291 | 422 | 706 | 1153 | 1645 | 2219 | 2680 | 3642
All Regions | All | 26081 | 39510.2 | 1193 | 702 | 4 | 80 | 286 | 423 | 690 | 1081 | 1561 | 2092 | 2477 | 3415

§ Does not include pregnant women, lactating women, or breast-fed children.

◆ Individual values may not add to totals due to rounding.

¶ Please see Discussion (Special Problem: Infants) (page 34) regarding limitations of Tapwater estimates for infants <1 year.

* Value not reported due to insufficient number of observations.[brr] 0 Less than 0.5 g/day.

Set D. Table 28 Tapwater Intake (g/day) of Males by Broad Age Category and Geographic Region (All Seasons) ^§◆¶^

Region | Age (yr) | Nunber of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Region | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Northeast | < 1 | 36 | 38.9 | 256 | 182 | 30 | * | * | 0 | 80 | 240 | 400 | 522 | * | *
| 1–10 | 674 | 765.4 | 564 | 340 | 13 | 22 | 100 | 192 | 327 | 508 | 717 | 1017 | 1194 | 1563
| 11–19 | 660 | 772.9 | 820 | 477 | 19 | 30 | 161 | 286 | 496 | 758 | 1081 | 1405 | 1735 | 2448
| 20–64 | 1226 | 2310.2 | 1202 | 648 | 19 | 100 | 339 | 481 | 741 | 1116 | 1537 | 1982 | 2312 | 3335
| 65+ | 217 | 375.2 | 1371 | 696 | 47 | * | 590 | 713 | 971 | 1245 | 1718 | 2071 | 2218 | *
| All | 2813 | 4262.6 | 1025 | 641 | 12 | 52 | 218 | 323 | 566 | 927 | 1360 | 1805 | 2139 | 2989
Midwest | < 1 | 53 | 59.5 | 273 | 230 | 32 | * | * | 0 | 80 | 240 | 361 | 569 | * | *
| 1–10 | 796 | 903.3 | 790 | 414 | 15 | 56 | 252 | 335 | 501 | 720 | 1016 | 1369 | 1550 | 2061
| 11–19 | 785 | 942.5 | 1045 | 590 | 21 | 122 | 281 | 412 | 626 | 927 | 1359 | 1809 | 2173 | 2994
| 20–64 | 1325 | 2442.6 | 1469 | 778 | 21 | 220 | 461 | 612 | 949 | 1354 | 1827 | 2415 | 2922 | 4120
| 65+ | 238 | 440.3 | 1577 | 683 | 44 | * | 662 | 775 | 1144 | 1520 | 1896 | 2459 | 2750 | *
| All | 3197 | 4788.2 | 1252 | 740 | 13 | 108 | 311 | 454 | 720 | 1128 | 1656 | 2178 | 2561 | 3742
South | < 1 | 74 | 72.3 | 292 | 259 | 30 | * | 0 | 0 | 80 | 240 | 414 | 640 | 832 | *
| 1–10 | 974 | 1005.9 | 852 | 440 | 14 | 35 | 264 | 360 | 546 | 779 | 1098 | 1425 | 1733 | 2162
| 11–19 | 969 | 1071.3 | 1199 | 642 | 21 | 124 | 365 | 483 | 757 | 1074 | 1529 | 2033 | 2288 | 3249
| 20–64 | 1645 | 2707.0 | 1614 | 841 | 21 | 239 | 501 | 670 | 1025 | 1488 | 2056 | 2760 | 3187 | 4332
| 65+ | 360 | 577.4 | 1669 | 722 | 38 | * | 611 | 827 | 1170 | 1527 | 2131 | 2668 | 2868 | *
| All | 4022 | 5433.9 | 1379 | 797 | 13 | 80 | 360 | 499 | 813 | 1234 | 1805 | 2424 | 2842 | 4040
West | < 1 | 37 | 48.6 | 335 | 278 | 46 | * | * | 0 | 211 | 240 | 480 | 756 | * | *
| 1–10 | 410 | 549.2 | 819 | 434 | 21 | 124 | 240 | 317 | 489 | 753 | 1084 | 1429 | 1610 | 2199
| 11–19 | 430 | 576.5 | 1088 | 623 | 30 | 86 | 292 | 380 | 617 | 1009 | 1427 | 1924 | 2265 | 3260
| 20–64 | 827 | 1708.3 | 1550 | 852 | 30 | 115 | 433 | 586 | 960 | 1397 | 1999 | 2692 | 3203 | 4152
| 65+ | 152 | 305.1 | 1618 | 662 | 54 | * | 627 | 869 | 1250 | 1508 | 1962 | 2554 | 2867 | *
| All | 1856 | 3187.7 | 1329 | 799 | 19 | 86 | 303 | 439 | 738 | 1213 | 1737 | 2357 | 2867 | 3928
All Regions | All | 11888 | 17672.6 | 1250 | 759 | 7 | 80 | 291 | 426 | 706 | 1123 | 1634 | 2205 | 2673 | 3760

§ Does not include breast-fed children.

◆ Individual values may not add to totals due to rounding.

¶ Please see Discussion (Special Problem: Infants) (page 34) regarding limitations of Tapwater estimates for infants <1 year.

* Value not reported due to insufficient number of observations.

0 Less than 0.5 g/day.

Set D. Table 29 Tapwater Intake (g/day) of Females by Broad Age Category and Geographic Region (All Seasons) ^§◆¶^

Region | Age (yr) | Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Region | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Northeast | < 1 | 48 | 56.8 | 210 | 229 | 33 | * | * | 0 | 6 | 178 | 275 | 532 | * | *
| 1–10 | 649 | 753.8 | 573 | 360 | 14 | 10 | 113 | 187 | 328 | 511 | 749 | 1016 | 1239 | 1693
| 11–19 | 664 | 792.1 | 755 | 451 | 18 | 37 | 168 | 236 | 464 | 695 | 946 | 1286 | 1596 | 2137
| 20–64 | 1657 | 3237.9 | 1134 | 548 | 13 | 164 | 406 | 511 | 767 | 1057 | 1418 | 1822 | 2100 | 2849
| 65+ | 367 | 584.2 | 1213 | 525 | 27 | * | 531 | 650 | 851 | 1103 | 1500 | 1885 | 2162 | *
| All | 3385 | 5424.8 | 999 | 560 | 10 | 70 | 234 | 356 | 610 | 923 | 1306 | 1702 | 2015 | 2648
Midwest | < 1 | 48 | 55.0 | 329 | 242 | 35 | * | * | 18 | 193 | 240 | 443 | 720 | * | *
| 1–10 | 709 | 797.5 | 721 | 363 | 14 | 65 | 258 | 320 | 465 | 662 | 922 | 1189 | 1419 | 1868
| 11–19 | 826 | 965.5 | 858 | 492 | 17 | 46 | 224 | 320 | 506 | 791 | 1139 | 1439 | 1701 | 2517
| 20–64 | 1647 | 3150.8 | 1323 | 655 | 16 | 112 | 372 | 539 | 880 | 1248 | 1690 | 2141 | 2498 | 3368
| 65+ | 366 | 597.2 | 1450 | 529 | 28 | * | 693 | 836 | 1097 | 1420 | 1746 | 2167 | 2374 | *
| All | 3596 | 5566.0 | 1160 | 639 | 11 | 85 | 281 | 424 | 686 | 1081 | 1538 | 1971 | 2320 | 3042
South | < 1 | 76 | 74.0 | 341 | 299 | 34 | * | 0 | 0 | 160 | 245 | 480 | 728 | 805 | *
| 1–10 | 954 | 1000.9 | 785 | 409 | 13 | 92 | 265 | 323 | 486 | 718 | 1014 | 1329 | 1566 | 2050
| 11–19 | 1013 | 1082.8 | 986 | 511 | 16 | 87 | 300 | 419 | 633 | 919 | 1254 | 1669 | 1948 | 2382
| 20–64 | 2335 | 3935.7 | 1365 | 668 | 14 | 119 | 478 | 602 | 895 | 1277 | 1736 | 2242 | 2566 | 3335
| 65+ | 610 | 870.7 | 1405 | 628 | 25 | 260 | 560 | 699 | 989 | 1306 | 1754 | 2237 | 2557 | 3121
| All | 4988 | 6964.1 | 1217 | 653 | 9 | 100 | 333 | 480 | 743 | 1118 | 1585 | 2091 | 2390 | 3081
West | < 1 | 31 | 39.2 | 395 | 276 | 50 | * | * | * | 240 | 355 | 558 | * | * | *
| 1–10 | 439 | 578.0 | 747 | 405 | 19 | 69 | 203 | 293 | 453 | 666 | 978 | 1293 | 1473 | 1872
| 11–19 | 454 | 621.3 | 902 | 526 | 25 | 68 | 225 | 335 | 522 | 821 | 1180 | 1640 | 1941 | 2488
| 20–64 | 1069 | 2252.5 | 1378 | 776 | 24 | 116 | 363 | 503 | 841 | 1257 | 1794 | 2305 | 2782 | 3913
| 65+ | 231 | 391.9 | 1483 | 597 | 39 | * | 719 | 837 | 1061 | 1395 | 1765 | 2332 | 2693 | *
| All | 2224 | 3882.9 | 1209 | 730 | 15 | 92 | 286 | 411 | 671 | 1102 | 1576 | 2152 | 2530 | 3399
All Regions | All | 14193 | 21837.6 | 1147 | 648 | 5 | 80 | 281 | 421 | 676 | 1049 | 1505 | 1988 | 2316 | 3097

§ Does not include pregnant women, lactating women, or breast-fed children.

◆ Individual values may not add to totals due to rounding.

¶ Please see Discussion (Special Problem: Infants) (page 34) regarding limitations of Tapwater estimates for infants <1 year.

* Value not reported due to insufficient number of observations.

0 Less than 0.5 g/day.

Set D. Table 30 Tapwater Intake (g/day) of Both Sexes by Broad Age Category and Season (All Regions) ^§◆¶^

Season | Age (yr) | Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Season | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Spring | < 1 | 63 | 78.9 | 270 | 263 | 33 | * | * | 0 | 74 | 240 | 396 | 634 | * | *
| 1–10 | 1117 | 1511.9 | 744 | 394 | 12 | 60 | 207 | 290 | 456 | 682 | 965 | 1299 | 1526 | 1872
| 11–19 | 1332 | 1760.4 | 997 | 583 | 16 | 80 | 267 | 386 | 597 | 874 | 1293 | 1750 | 2137 | 2871
| 20–64 | 3997 | 5258.9 | 1361 | 723 | 11 | 170 | 425 | 559 | 867 | 1242 | 1732 | 2259 | 2709 | 3729
| 65+ | 770 | 996.5 | 1483 | 621 | 22 | 439 | 639 | 782 | 1039 | 1387 | 1867 | 2291 | 2612 | 3201
| All | 7279 | 9606.6 | 1201 | 695 | 8 | 86 | 315 | 443 | 698 | 1084 | 1569 | 2101 | 2461 | 3335
Summer | < 1 | 107 | 130.1 | 334 | 278 | 27 | * | 0 | 0 | 183 | 240 | 480 | 675 | 762 | *
| 1–10 | 1321 | 1568.1 | 794 | 438 | 12 | 56 | 241 | 313 | 481 | 718 | 1016 | 1394 | 1651 | 2130
| 11–19 | 1356 | 1672.0 | 1040 | 600 | 16 | 64 | 263 | 395 | 610 | 939 | 1360 | 1839 | 2179 | 2831
| 20–64 | 2327 | 5534.3 | 1429 | 781 | 16 | 160 | 443 | 587 | 905 | 1316 | 1766 | 2397 | 2927 | 4065
| 65+ | 513 | 1025.1 | 1576 | 747 | 33 | 314 | 688 | 782 | 1074 | 1438 | 1978 | 2517 | 2933 | 3797
| All | 5624 | 9929.6 | 1264 | 754 | 10 | 83 | 308 | 460 | 738 | 1134 | 1627 | 2180 | 2652 | 3872
Fall | < 1 | 108 | 109.7 | 317 | 228 | 22 | * | 0 | 0 | 160 | 255 | 448 | 712 | 800 | *
| 1–10 | 1619 | 1648.4 | 728 | 404 | 10 | 84 | 219 | 282 | 439 | 656 | 948 | 1291 | 1507 | 2012
| 11–19 | 1584 | 1717.0 | 905 | 519 | 13 | 45 | 200 | 296 | 529 | 835 | 1207 | 1604 | 1845 | 2372
| 20–64 | 2692 | 5444.0 | 1332 | 709 | 14 | 144 | 397 | 544 | 837 | 1227 | 1688 | 2222 | 2617 | 3585
| 65+ | 632 | 1073.3 | 1411 | 601 | 24 | 322 | 596 | 747 | 988 | 1326 | 1721 | 2247 | 2586 | 3071
| All | 6635 | 9992.4 | 1156 | 678 | 8 | 81 | 272 | 404 | 665 | 1057 | 1512 | 2037 | 2394 | 3262
Winter | < 1 | 125 | 125.7 | 278 | 256 | 23 | * | 0 | 0 | 80 | 240 | 386 | 623 | 847 | *
| 1–10 | 1548 | 1625.7 | 680 | 397 | 10 | 33 | 143 | 252 | 401 | 604 | 892 | 1202 | 1413 | 1998
| 11–19 | 1529 | 1675.6 | 918 | 530 | 14 | 62 | 248 | 360 | 556 | 826 | 1165 | 1563 | 1958 | 2543
| 20–64 | 2715 | 5507.7 | 1341 | 692 | 13 | 115 | 400 | 557 | 858 | 1236 | 1750 | 2217 | 2576 | 3490
| 65+ | 626 | 1047.1 | 1373 | 572 | 23 | 228 | 499 | 720 | 1003 | 1322 | 1693 | 2124 | 2414 | 2926
| All | 6543 | 9981.8 | 1152 | 672 | 8 | 68 | 256 | 399 | 658 | 1047 | 1534 | 2039 | 2381 | 3187
All Seasons | All | 26081 | 39510.2 | 1193 | 702 | 4 | 80 | 286 | 423 | 690 | 1081 | 1561 | 2092 | 2477 | 3415

§ Does not include pregnant women, lactating women, or breast-fed children.

◆ Individual values may not add to totals due to rounding.

¶ Please see Discussion (Special Problem: Infants) (page 34) regarding limitations of Tapwater estimates for infants <1 year.

* Value not reported due to insufficient number of observations.

0 Less them 0.5 g/day.

Set D. Table 31 Tapwater Intake (g/day) of Males by Broad Age Category and Season (All Regions)^§◆¶^

Season | Age (yr) | Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Season | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Spring | < 1 | 30 | 39.3 | 227 | 189 | 35 | * | * | * | 80 | 240 | 332 | * | * | *
| 1–10 | 581 | 795.7 | 765 | 401 | 17 | 60 | 192 | 291 | 479 | 720 | 1010 | 1302 | 1560 | 1885
| 11–19 | 657 | 883.8 | 1116 | 633 | 25 | 65 | 317 | 418 | 666 | 1005 | 1444 | 1961 | 2283 | 2994
| 20–64 | 1858 | 2425.7 | 1484 | 798 | 19 | 183 | 464 | 607 | 927 | 1357 | 1889 | 2500 | 2937 | 4120
| 65+ | 326 | 421.0 | 1603 | 682 | 38 | * | 639 | 811 | 1120 | 1532 | 2047 | 2447 | 2741 | *
| All | 3452 | 4565.5 | 1287 | 762 | 13 | 80 | 320 | 467 | 746 | 1150 | 1694 | 2262 | 2709 | 3767
Summer | < 1 | 63 | 71.6 | 310 | 230 | 29 | * | * | 0 | 160 | 240 | 480 | 583 | * | *
| 1–10 | 655 | 779.4 | 816 | 460 | 18 | 56 | 241 | 313 | 482 | 724 | 1072 | 1444 | 1711 | 2162
| 11–19 | 642 | 800.2 | 1140 | 653 | 26 | 84 | 308 | 416 | 650 | 1016 | 1520 | 1987 | 2264 | 3169
| 20–64 | 952 | 2284.1 | 1559 | 898 | 29 | 191 | 454 | 587 | 960 | 1399 | 1954 | 2804 | 3403 | 4415
| 65+ | 185 | 404.2 | 1778 | 854 | 63 | * | 778 | 860 | 1203 | 1617 | 2245 | 2870 | 3435 | *
| All | 2497 | 4339.5 | 1348 | 852 | 17 | 88 | 314 | 454 | 741 | 1196 | 1745 | 2388 | 3041 | 4120
Fall | < 1 | 47 | 50.4 | 306 | 244 | 36 | * | * | 27 | 80 | 240 | 480 | 748 | * | *
| 1–10 | 840 | 836.1 | 755 | 417 | 14 | 95 | 229 | 287 | 450 | 678 | 996 | 1357 | 1526 | 2048
| 11–19 | 776 | 833.4 | 980 | 560 | 20 | 41 | 230 | 320 | 587 | 897 | 1291 | 1677 | 1976 | 2826
| 20–64 | 1031 | 2085.3 | 1383 | 764 | 24 | 74 | 344 | 554 | 868 | 1259 | 1773 | 2354 | 2854 | 4037
| 65+ | 219 | 424.1 | 1469 | 639 | 43 | * | 552 | 766 | 1047 | 1376 | 1827 | 2385 | 2706 | *
| All | 2913 | 4229.3 | 1175 | 712 | 13 | 74 | 262 | 397 | 658 | 1063 | 1528 | 2084 | 2494 | 3467
Winter | < 1 | 60 | 58.1 | 294 | 288 | 37 | * | * | 0 | 80 | 240 | 400 | 756 | * | *
| 1–10 | 778 | 812.6 | 709 | 413 | 15 | 33 | 152 | 281 | 421 | 629 | 922 | 1250 | 1436 | 2061
| 11–19 | 769 | 845.8 | 964 | 550 | 20 | 102 | 253 | 369 | 587 | 867 | 1207 | 1659 | 2015 | 2623
| 20–64 | 1182 | 2373.0 | 1407 | 707 | 21 | 160 | 421 | 569 | 896 | 1309 | 1793 | 2357 | 2737 | 3559
| 65+ | 237 | 448.8 | 1447 | 580 | 38 | * | 512 | 737 | 1052 | 1432 | 1806 | 2146 | 2484 | *
| All | 3026 | 4538.3 | 1189 | 689 | 13 | 80 | 282 | 406 | 675 | 1086 | 1592 | 2119 | 2487 | 3267
All Seasons | All | 11888 | 17672.6 | 1250 | 759 | 7 | 80 | 291 | 426 | 706 | 1123 | 1634 | 2205 | 2673 | 3760

§ Does not include breast-fed children.

◆ Individual values may not add to totals due to rounding.

¶ Please see Discussion (Special Problem: Infants) (page 34) regarding limitations of Tapwater estimates for infants <1 year.

* Value not reported due to insufficient number of observations.

0 Less than 0.5 g/day.

Set D. Table 32 Tapwater Intake (g/day) of Females by Broad Age Category and Season (All Regions)^§◆¶^

Season | Age (yr) | Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Season | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Spring | < 1 | 33 | 39.6 | 313 | 317 | 55 | * | * | 0 | 74 | 240 | 500 | 775 | * | *
| 1–10 | 536 | 716.2 | 721 | 384 | 17 | 92 | 208 | 288 | 448 | 651 | 938 | 1292 | 1481 | 1846
| 11–19 | 675 | 876.6 | 876 | 500 | 19 | 80 | 224 | 343 | 550 | 787 | 1135 | 1507 | 1791 | 2449
| 20–64 | 2139 | 2833.2 | 1256 | 633 | 14 | 159 | 406 | 537 | 810 | 1181 | 1607 | 2037 | 2349 | 3198
| 65+ | 444 | 575.5 | 1395 | 557 | 26 | 332 | 639 | 732 | 1003 | 1333 | 1691 | 2159 | 2472 | 2971
| All | 3827 | 5041.1 | 1123 | 619 | 10 | 95 | 308 | 429 | 664 | 1033 | 1475 | 1930 | 2240 | 3017
Summer | < 1 | 44 | 58.4 | 363 | 327 | 49 | * | * | 0 | 183 | 240 | 524 | 728 | * | *
| 1–10 | 666 | 788.8 | 772 | 414 | 16 | 33 | 241 | 312 | 480 | 713 | 991 | 1321 | 1579 | 2053
| 11–19 | 714 | 871.8 | 948 | 532 | 20 | 55 | 230 | 369 | 583 | 860 | 1215 | 1653 | 1993 | 2572
| 20–64 | 1375 | 3250.3 | 1337 | 671 | 18 | 148 | 436 | 578 | 878 | 1260 | 1670 | 2172 | 2555 | 3395
| 65+ | 328 | 620.9 | 1444 | 635 | 35 | * | 599 | 743 | 959 | 1360 | 1822 | 2267 | 2634 | *
| All | 3127 | 5590.2 | 1199 | 661 | 12 | 79 | 305 | 467 | 736 | 1099 | 1554 | 2053 | 2423 | 3254
Fall | < 1 | 61 | 59.3 | 326 | 215 | 28 | * | * | 0 | 193 | 287 | 427 | 712 | * | *
| 1–10 | 779 | 812.2 | 700 | 388 | 14 | 79 | 195 | 278 | 425 | 623 | 921 | 1183 | 1457 | 1899
| 11–19 | 808 | 883.5 | 835 | 466 | 16 | 59 | 182 | 268 | 476 | 774 | 1137 | 1494 | 1712 | 2081
| 20–64 | 1661 | 3358.8 | 1299 | 672 | 16 | 188 | 409 | 533 | 824 | 1210 | 1650 | 2170 | 2512 | 3344
| 65+ | 413 | 649.2 | 1373 | 573 | 28 | 322 | 631 | 739 | 958 | 1303 | 1663 | 2187 | 2457 | 3071
| All | 3722 | 5763.0 | 1142 | 651 | 11 | 98 | 279 | 408 | 667 | 1050 | 1494 | 1992 | 2305 | 3148
Winter | < 1 | 65 | 67.6 | 264 | 226 | 28 | * | * | 0 | 80 | 240 | 386 | 620 | * | *
| 1–10 | 770 | 813.1 | 652 | 380 | 14 | 38 | 138 | 217 | 389 | 572 | 864 | 1158 | 1347 | 1682
| 11–19 | 760 | 829.7 | 871 | 505 | 18 | 20 | 244 | 355 | 523 | 780 | 1134 | 1495 | 1842 | 2543
| 20–64 | 1533 | 3134.7 | 1291 | 675 | 17 | 111 | 375 | 542 | 823 | 1186 | 1688 | 2146 | 2469 | 3400
| 65+ | 389 | 598.3 | 1316 | 560 | 28 | 162 | 449 | 703 | 956 | 1258 | 1608 | 2069 | 2335 | 2926
| All | 3517 | 5443.4 | 1121 | 656 | 11 | 68 | 244 | 391 | 646 | 1028 | 1491 | 1977 | 2289 | 3076
All Seasons | All | 14193 | 21837.6 | 1147 | 648 | 5 | 80 | 281 | 421 | 676 | 1049 | 1505 | 1988 | 2316 | 3097

§ Does not include pregnant women, lactating women, or breast-fed children.

◆ Individual values may not add to totals due to rounding.

¶ Please see Discussion (Special Problem: Infants) (page 34) regarding limitations of Tapwater estimates for infants <1 year.

* Value not reported due to insufficient number of observations.

0 Less than 0.5 g/day.

### E TAPWATER INTAKE (g/kg/day)

Set E. Table 33 Tapwater Intake (g/kg/day) by Broad Age Category and Sex (All Regions, All Seasons) ^§◆¶^

Sex | Age (yr) | Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Sex | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Both Sexes | < 1 | 403 | 444.3 | 43.5 | 42.5 | 2.1 | 0.0 | 0.0 | 0.0 | 15.3 | 35.3 | 54.7 | 101.8 | 126.5 | 220.5
| 1–10 | 5605 | 6354.1 | 35.5 | 22.9 | 0.3 | 2.7 | 8.3 | 12.5 | 19.6 | 30.5 | 46.0 | 64.4 | 79.4 | 113.9
| 11–19 | 5801 | 6824.9 | 18.2 | 10.8 | 0.1 | 1.2 | 4.3 | 6.5 | 10.6 | 16.3 | 23.6 | 32.3 | 38.9 | 52.6
| 20–64 | 11731 | 21744.9 | 19.9 | 10.8 | 0.1 | 2.2 | 5.9 | 8.0 | 12.4 | 18.2 | 25.3 | 33.7 | 40.0 | 54.8
| 65+ | 2541 | 4142.0 | 21.8 | 9.8 | 0.2 | 4.5 | 8.7 | 10.9 | 15.0 | 20.3 | 27.1 | 34.7 | 40.0 | 51.3
| All | 26081 | 39510.2 | 22.6 | 15.4 | 0.1 | 1.7 | 5.8 | 8.2 | 13.0 | 19.4 | 28.0 | 39.8 | 50.0 | 79.8
Males | < 1 | 200 | 219.4 | 38.3 | 34.9 | 2.5 | * | 0.0 | 0.0 | 14.7 | 32.1 | 47.4 | 86.8 | 117.5 | *
| 1–10 | 2854 | 3223.8 | 36.5 | 23.5 | 0.4 | 2.6 | 8.2 | 12.4 | 20.3 | 31.5 | 47.2 | 65.9 | 81.7 | 115.5
| 11–19 | 2844 | 3363.2 | 18.8 | 11.0 | 0.2 | 1.4 | 4.6 | 6.8 | 11.1 | 16.7 | 24.4 | 33.0 | 39.7 | 53.6
| 20–64 | 5023 | 9168.1 | 18.7 | 10.5 | 0.1 | 2.1 | 5.2 | 7.3 | 11.4 | 17.0 | 23.7 | 31.9 | 38.1 | 54.0
| 65+ | 967 | 1698.1 | 21.4 | 9.8 | 0.3 | 5.1 | 8.4 | 10.6 | 15.0 | 20.3 | 26.8 | 33.4 | 38.6 | 51.1
| All | 11888 | 17672.6 | 22.5 | 16.0 | 0.1 | 1.6 | 5.5 | 7.8 | 12.5 | 18.9 | 27.9 | 40.2 | 52.0 | 82.9
Females | < 1 | 203 | 225.0 | 48.7 | 48.4 | 3.4 | * | 0.0 | 0.0 | 16.3 | 40.7 | 60.7 | 105.0 | 147.0 | *
| 1–10 | 2751 | 3130.2 | 34.5 | 22.1 | 0.4 | 2.7 | 8.4 | 12.6 | 19.2 | 29.4 | 44.7 | 63.0 | 75.7 | 108.1
| 11–19 | 2957 | 3461.7 | 17.6 | 10.4 | 0.2 | 1.1 | 4.0 | 6.1 | 10.2 | 15.7 | 22.7 | 31.5 | 38.4 | 49.7
| 20–64 | 6708 | 12576.8 | 20.8 | 11.0 | 0.1 | 2.2 | 6.4 | 8.7 | 13.1 | 19.1 | 26.2 | 34.8 | 41.7 | 55.0
| 65+ | 1574 | 2443.9 | 22.0 | 9.8 | 0.2 | 3.9 | 8.9 | 11.1 | 15.1 | 20.2 | 27.5 | 35.4 | 41.1 | 51.3
| All | 14193 | 21837.6 | 22.7 | 15.0 | 0.1 | 1.8 | 6.1 | 8.7 | 13.4 | 19.7 | 28.0 | 39.3 | 48.8 | 75.6

§ Does not include pregnant women, lactating women, or breast-fed children.

◆ Individual values may not add to totals due to rounding.

¶ Please see Discussion (Special Problem: Infants) (page 34) regarding limitations of Tapwater estimates for infants <1 year.

* Value not reported due to insufficient number of observations.

0.0 Less than 0.05 g/day.

Set E. Table 34 Tapwater Intake (g/kg/day) by Fine Age Category and Sex (All Regions, All Seasons) ^§◆¶^

Sex | Age (yr) | Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Sex | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Both Sexes | < 0.5 | 182 | 201.2 | 52.4 | 53.2 | 3.9 | * | 0.0 | 0.0 | 14.8 | 37.8 | 66.1 | 128.3 | 155.6 | *
| 0.5–0.9 | 221 | 243.2 | 36.2 | 29.2 | 2.0 | * | 0.0 | 0.0 | 15.3 | 32.2 | 48.1 | 69.4 | 102.9 | *
| 1– 3 | 1498 | 1687.7 | 46.8 | 28.1 | 0.7 | 2.7 | 11.8 | 17.8 | 27.2 | 41.4 | 60.4 | 82.1 | 101.6 | 140.6
| 4– 6 | 1702 | 1923.9 | 37.9 | 21.8 | 0.5 | 3.4 | 10.3 | 14.9 | 21.9 | 33.3 | 48.7 | 69.3 | 81.1 | 103.4
| 7–10 | 2405 | 2742.4 | 26.9 | 15.3 | 0.3 | 2.2 | 7.4 | 10.3 | 16.0 | 24.0 | 35.5 | 47.3 | 55.2 | 70.5
| 11–14 | 2803 | 3146.9 | 20.2 | 11.6 | 0.2 | 1.5 | 4.9 | 7.5 | 11.9 | 18.1 | 26.2 | 35.7 | 41.9 | 55.0
| 15–19 | 2998 | 3677.9 | 16.4 | 9.6 | 0.2 | 1.0 | 3.9 | 5.7 | 9.6 | 14.8 | 21.5 | 29.0 | 35.0 | 46.3
| 20–44 | 7171 | 13444.5 | 18.6 | 10.7 | 0.1 | 1.6 | 4.9 | 7.1 | 11.2 | 16.8 | 23.7 | 32.2 | 38.4 | 53.4
| 45–64 | 4560 | 8300.4 | 22.0 | 10.8 | 0.2 | 4.4 | 8.0 | 10.3 | 14.7 | 20.2 | 27.2 | 35.5 | 42.1 | 57.8
| 65–74 | 1663 | 2740.2 | 21.9 | 9.9 | 0.2 | 4.6 | 8.7 | 10.9 | 15.1 | 20.2 | 27.2 | 35.2 | 40.6 | 51.6
| 75+ | 878 | 1401.8 | 21.6 | 9.5 | 0.3 | 3.8 | 8.8 | 10.7 | 15.0 | 20.5 | 27.1 | 33.9 | 38.6 | 47.2
| All | 26081 | 39510.2 | 22.6 | 15.4 | 0.1 | 1.7 | 5.8 | 8.2 | 13.0 | 19.4 | 28.0 | 39.8 | 50.0 | 79.8
Males | < 0.5 | 87 | 96.4 | 43.3 | 42.8 | 4.6 | * | 0.0 | 0.0 | 9.4 | 33.1 | 58.8 | 112.4 | 132.3 | *
| 0.5–0.9 | 113 | 122.9 | 34.3 | 26.7 | 2.5 | * | 0.0 | 1.6 | 18.4 | 29.8 | 43.9 | 65.5 | 86.8 | *
| 1– 3 | 775 | 879.6 | 48.4 | 29.0 | 1.0 | 1.8 | 12.6 | 18.1 | 28.1 | 43.4 | 61.6 | 84.5 | 102.9 | 146.0
| 4– 6 | 883 | 991.4 | 38.8 | 21.7 | 0.7 | 3.5 | 10.8 | 15.5 | 23.5 | 34.4 | 48.9 | 68.9 | 81.5 | 105.5
| 7–10 | 1196 | 1352.9 | 27.2 | 15.8 | 0.5 | 2.2 | 6.9 | 9.9 | 15.7 | 24.1 | 35.6 | 49.3 | 56.6 | 74.6
| 11–14 | 1395 | 1571.8 | 20.9 | 11.9 | 0.3 | 1.8 | 5.2 | 7.7 | 12.4 | 18.8 | 27.3 | 36.6 | 43.0 | 56.8
| 15–19 | 1449 | 1791.4 | 16.9 | 9.9 | 0.3 | 1.2 | 4.3 | 6.0 | 9.8 | 15.3 | 21.8 | 29.8 | 35.6 | 48.3
| 20–44 | 3146 | 5702.7 | 17.5 | 10.5 | 0.2 | 1.4 | 4.3 | 6.3 | 10.3 | 15.8 | 22.2 | 30.8 | 37.0 | 53.6
| 45–64 | 1877 | 3465.4 | 20.6 | 10.2 | 0.2 | 4.3 | 7.5 | 9.6 | 13.7 | 18.9 | 25.9 | 33.3 | 39.3 | 55.2
| 65–74 | 656 | 1172.3 | 21.4 | 9.8 | 0.4 | 5.0 | 8.0 | 10.5 | 15.2 | 20.0 | 26.5 | 33.4 | 38.6 | 53.6
| 75+ | 311 | 525.8 | 21.6 | 9.7 | 0.6 | * | 8.7 | 10.6 | 14.4 | 20.5 | 27.5 | 33.3 | 38.4 | *
| All | 11888 | 17672.6 | 22.5 | 16.0 | 0.1 | 1.6 | 5.5 | 7.8 | 12.5 | 18.9 | 27.9 | 40.2 | 52.0 | 82.9
Females | < 0.5 | 95 | 104.7 | 60.8 | 60.2 | 6.2 | * | 0.0 | 0.0 | 25.2 | 47.4 | 71.8 | 147.0 | 200.5 | *
| 0.5–0.9 | 108 | 120.2 | 38.2 | 31.5 | 3.0 | * | 0.0 | 0.0 | 11.8 | 35.3 | 53.3 | 79.3 | 104.6 | *
| 1– 3 | 723 | 808.2 | 45.1 | 27.1 | 1.0 | 3.7 | 11.1 | 17.6 | 25.0 | 40.0 | 58.4 | 79.2 | 98.8 | 139.6
| 4– 6 | 819 | 932.5 | 37.0 | 21.9 | 0.8 | 3.2 | 8.9 | 14.1 | 20.9 | 32.2 | 48.7 | 69.3 | 79.4 | 100.6
| 7–10 | 1209 | 1389.5 | 26.7 | 14.8 | 0.4 | 2.2 | 7.9 | 10.5 | 16.4 | 24.0 | 35.4 | 46.1 | 53.7 | 69.0
| 11–14 | 1408 | 1575.1 | 19.4 | 11.3 | 0.3 | 1.5 | 4.8 | 7.3 | 11.4 | 17.5 | 25.3 | 34.5 | 40.8 | 52.8
| 15–19 | 1549 | 1886.5 | 16.0 | 9.4 | 0.2 | 0.8 | 3.4 | 5.6 | 9.4 | 14.3 | 20.9 | 28.2 | 34.4 | 45.1
| 20–44 | 4025 | 7741.7 | 19.4 | 10.8 | 0.2 | 1.8 | 5.5 | 7.8 | 12.0 | 17.6 | 24.6 | 33.3 | 39.6 | 53.2
| 45–64 | 2683 | 4835.1 | 23.0 | 11.1 | 0.2 | 4.6 | 8.4 | 10.8 | 15.5 | 21.3 | 28.0 | 36.7 | 44.1 | 58.7
| 65–74 | 1007 | 1567.9 | 22.3 | 10.0 | 0.3 | 4.6 | 8.8 | 11.4 | 15.0 | 20.3 | 28.0 | 36.3 | 42.5 | 51.3
| 75+ | 567 | 876.0 | 21.5 | 9.4 | 0.4 | 2.7 | 9.0 | 11.0 | 15.1 | 20.2 | 26.9 | 34.2 | 38.6 | 50.0
| All | 14193 | 21837.6 | 22.7 | 15.0 | 0.1 | 1.8 | 6.1 | 8.7 | 13.4 | 19.7 | 28.0 | 39.3 | 48.8 | 75.6

§ Does not include pregnant women, lactating women, or breast-fed children.

◆ Individual values may not add to totals due to rounding.

¶ Please see Discussion (Special Problem: Infants) (page 34) regarding limitations of Tapwater estimates for infants <1 year.

* Value not reported due to insufficient number of observations.

0.0 Less than 0.05 g/kg/day.

Set E. Table 35 Tapwater Intake (g/kg/day) of Pregnant Women, Lactating Women, and Breast-fed Children (All Regions, All Seasons) ^¶^

| Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
| Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 5 | 10 | 25 | 50 | 75 | 90 | 95
Pregnant women | 188 | 327.5 | 18.3 | 10.4 | 0.8 | 4.9 | 5.9 | 10.7 | 16.4 | 23.8 | 34.5 | 39.6
Lactating women | 77 | 151.2 | 21.4 | 9.8 | 1.1 | 7.4 | 9.8 | 14.8 | 20.5 | 26.8 | 35.1 | 37.4
Breast-fed children
Both sexes
All ages | 100 | 121.0 | 21.7 | 25.4 | 2.5 | 0.0 | 0.0 | 0.0 | 11.8 | 37.8 | 55.8 | 60.1
< 0.5 yr | 62 | 74.4 | 20.5 | 27.9 | 3.5 | * | 0.0 | 0.0 | 0.0 | 37.8 | 56.1 | *
≥ 0.5 yr | 38 | 46.6 | 23.8 | 21.1 | 3.4 | * | 0.0 | 9.6 | 22.0 | 36.2 | 44.0 | *
Males
All ages | 42 | 49.4 | 15.7 | 19.2 | 3.0 | * | 0.0 | 0.0 | 10.1 | 31.1 | 51.4 | *
< 0.5 yr | 28 | 34.0 | 13.1 | 20.3 | 3.8 | * | * | 0.0 | 0.0 | 17.6 | * | *
≥ 0.5 yr | 14 | 15.5 | * | * | * | * | * | 10.3 | 22.0 | 34.3 | * | *
Females
All ages | 58 | 71.6 | 25.9 | 28.4 | 3.7 | * | 0.0 | 0.0 | 21.4 | 38.7 | 56.1 | *
< 0.5 yr | 34 | 40.5 | 26.7 | 31.8 | 5.5 | * | * | 0.0 | 25.1 | 52.9 | * | *
≥ 0.5 yr | 24 | 31.1 | * | * | * | * | * | 9.6 | 21.4 | 36.4 | * | *

¶ Please see Discussion (Special Problem: Infants) (page 34) regarding limitations of Tapwater estimates for infants <1 year.

* Value not reported due to insufficient number of observations.

0.0 Less than 0.05 g/kg/day.

Set E. Table 36 Tapwater Intake (g/kg/day) of Both Sexes by Broad Age Category and Geographic Region (All Seasons) ^§◆¶^

Region | Age (yr) | Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Region | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Northeast | < 1 | 84 | 95.7 | 36.9 | 43.2 | 4.7 | * | 0.0 | 0.0 | 8.8 | 27.2 | 52.9 | 76.9 | 104.6 | *
| 1–10 | 1323 | 1519.2 | 27.2 | 19.5 | 0.5 | 1.1 | 5.1 | 8.2 | 14.6 | 22.9 | 35.5 | 48.8 | 62.2 | 102.5
| 11–19 | 1324 | 1565.0 | 15.0 | 9.3 | 0.3 | 0.6 | 2.9 | 4.7 | 8.7 | 13.5 | 19.3 | 27.1 | 32.9 | 42.9
| 20–64 | 2883 | 5548.0 | 17.2 | 9.1 | 0.2 | 2.1 | 5.4 | 7.4 | 11.0 | 16.0 | 21.6 | 28.1 | 33.7 | 48.2
| 65+ | 584 | 959.4 | 19.6 | 9.1 | 0.4 | 3.8 | 8.5 | 10.3 | 13.6 | 18.1 | 23.7 | 30.0 | 34.7 | 50.6
| All | 6198 | 9687.3 | 18.8 | 12.9 | 0.2 | 1.3 | 4.7 | 7.1 | 11.2 | 16.5 | 23.2 | 32.4 | 40.5 | 63.4
Midwest | < 1 | 101 | 114.5 | 41.4 | 37.4 | 3.7 | * | 0.0 | 0.0 | 22.0 | 35.3 | 50.4 | 75.1 | 126.5 | *
| 1–10 | 1505 | 1700.8 | 36.3 | 22.2 | 0.6 | 3.4 | 10.0 | 14.1 | 21.0 | 31.2 | 47.2 | 63.7 | 77.0 | 109.2
| 11–19 | 1611 | 1908.0 | 17.9 | 10.6 | 0.3 | 1.1 | 4.3 | 6.4 | 10.4 | 15.8 | 23.3 | 31.4 | 38.9 | 50.0
| 20–64 | 2972 | 5593.4 | 19.8 | 10.5 | 0.2 | 2.4 | 5.8 | 7.9 | 12.5 | 18.4 | 25.6 | 33.1 | 38.3 | 53.1
| 65+ | 604 | 1037.5 | 22.1 | 9.3 | 0.4 | 4.6 | 8.9 | 11.5 | 15.6 | 20.9 | 27.4 | 33.2 | 37.8 | 52.4
| All | 6793 | 10354.2 | 22.6 | 15.1 | 0.2 | 1.8 | 5.8 | 8.2 | 13.2 | 19.7 | 28.1 | 39.5 | 50.3 | 76.8
South | < 1 | 150 | 146.3 | 43.7 | 39.7 | 3.2 | * | 0.0 | 0.0 | 12.6 | 34.1 | 62.9 | 106.7 | 117.5 | *
| 1–10 | 1928 | 2006.8 | 39.5 | 23.6 | 0.5 | 4.0 | 11.2 | 15.1 | 22.8 | 34.8 | 51.1 | 71.1 | 84.7 | 113.5
| 11–19 | 1982 | 2154.1 | 20.5 | 11.4 | 0.3 | 1.9 | 6.1 | 8.2 | 12.6 | 18.3 | 26.7 | 35.7 | 41.5 | 56.6
| 20–64 | 3980 | 6642.8 | 21.3 | 11.2 | 0.2 | 2.4 | 6.6 | 9.1 | 13.4 | 19.7 | 27.0 | 35.5 | 42.5 | 55.7
| 65+ | 970 | 1448.1 | 22.4 | 10.4 | 0.3 | 4.6 | 8.6 | 10.7 | 14.8 | 20.7 | 28.3 | 36.9 | 41.5 | 52.8
| All | 9010 | 12398.1 | 24.5 | 16.1 | 0.2 | 2.0 | 6.9 | 9.4 | 14.1 | 20.9 | 30.3 | 43.1 | 53.3 | 84.7
West | < 1 | 68 | 87.7 | 53.2 | 50.9 | 6.2 | * | 0.0 | 0.0 | 27.8 | 39.4 | 66.7 | 106.3 | 141.4 | *
| 1–10 | 849 | 1127.2 | 38.7 | 23.8 | 0.8 | 3.6 | 10.5 | 14.5 | 22.0 | 33.5 | 48.7 | 69.5 | 87.8 | 119.5
| 11–19 | 884 | 1197.8 | 18.4 | 10.7 | 0.4 | 1.3 | 4.4 | 6.9 | 11.0 | 16.9 | 23.7 | 32.1 | 39.4 | 53.2
| 20–64 | 1896 | 3960.7 | 21.4 | 12.2 | 0.3 | 1.6 | 5.6 | 7.9 | 13.0 | 19.4 | 27.3 | 36.5 | 44.4 | 59.1
| 65+ | 383 | 697.0 | 23.1 | 9.7 | 0.5 | 4.5 | 9.3 | 12.4 | 16.6 | 21.2 | 28.3 | 37.2 | 41.6 | 50.4
| All | 4080 | 7070.4 | 24.2 | 17.0 | 0.3 | 1.6 | 5.8 | 8.4 | 13.9 | 20.6 | 30.3 | 43.0 | 53.8 | 88.1
All Regions | All | 26081 | 39510.2 | 22.6 | 15.4 | 0.1 | 1.7 | 5.8 | 8.2 | 13.0 | 19.4 | 28.0 | 39.8 | 50.0 | 79.8

§ Does not include pregnant women, lactating women, or breast-fed children.

◆ Individual values may not add to totals due to rounding.

¶ Please see Discussion (Special Problem: Infants) (page 34) regarding limitations of Tapwater estimates for infants <1 year.

* Value not reported due to insufficient number of observations.

0.0 Less than 0.05 g/kg/day.

Set E. Table 37 Tapwater Intake (g/kg/day) of Males by Broad Age Category and Geographic Region (All Seasons) ^§◆¶^

Region | Age (yr) | Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Region | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Northeast | < 1 | 36 | 38.9 | 40.4 | 40.5 | 6.8 | * | * | 0.0 | 9.3 | 32.2 | 54.6 | 81.0 | * | *
| 1–10 | 674 | 765.4 | 27.2 | 19.5 | 0.8 | 1.3 | 5.1 | 7.8 | 14.2 | 23.2 | 35.8 | 48.9 | 62.4 | 95.8
| 11–19 | 660 | 772.9 | 14.9 | 9.1 | 0.4 | 0.5 | 2.9 | 4.7 | 8.2 | 13.3 | 19.5 | 27.6 | 32.6 | 42.9
| 20–64 | 1226 | 2310.2 | 15.5 | 8.7 | 0.2 | 1.4 | 4.3 | 6.2 | 9.6 | 14.3 | 19.8 | 26.5 | 30.7 | 40.0
| 65+ | 217 | 375.2 | 19.1 | 9.7 | 0.7 | * | 8.0 | 9.3 | 13.0 | 17.6 | 22.4 | 27.9 | 34.1 | *
| All | 2813 | 4262.6 | 18.0 | 13.1 | 0.2 | 1.1 | 4.1 | 6.2 | 10.2 | 15.4 | 22.2 | 31.8 | 40.0 | 64.0
Midwest | < 1 | 53 | 59.5 | 33.3 | 30.0 | 4.1 | * | * | 0.0 | 9.4 | 29.5 | 43.9 | 63.2 | * | *
| 1–10 | 796 | 903.3 | 37.8 | 24.0 | 0.9 | 3.9 | 9.7 | 13.6 | 21.4 | 32.2 | 49.4 | 65.7 | 80.3 | 124.6
| 11–19 | 785 | 942.5 | 18.6 | 10.8 | 0.4 | 1.8 | 4.7 | 6.7 | 11.1 | 16.2 | 23.8 | 32.7 | 39.4 | 50.7
| 20–64 | 1325 | 2442.6 | 18.6 | 10.3 | 0.3 | 3.1 | 5.6 | 7.3 | 11.6 | 17.2 | 23.5 | 30.9 | 37.0 | 53.0
| 65+ | 238 | 440.3 | 21.3 | 9.7 | 0.6 | * | 7.9 | 10.5 | 14.6 | 20.1 | 26.7 | 31.6 | 37.1 | *
| All | 3197 | 4788.2 | 22.7 | 16.2 | 0.3 | 2.4 | 5.7 | 7.9 | 12.5 | 19.1 | 27.9 | 40.7 | 52.5 | 81.1
South | < 1 | 74 | 72.3 | 39.4 | 35.9 | 4.2 | * | 0.0 | 0.0 | 12.6 | 32.0 | 62.0 | 99.3 | 112.4 | *
| 1–10 | 974 | 1005.9 | 40.2 | 23.8 | 0.8 | 2.4 | 11.5 | 15.7 | 23.5 | 35.5 | 51.4 | 70.8 | 86.0 | 115.5
| 11–19 | 969 | 1071.3 | 21.5 | 11.8 | 0.4 | 2.2 | 6.5 | 8.4 | 13.2 | 19.2 | 27.9 | 36.7 | 43.3 | 59.4
| 20–64 | 1645 | 2707.0 | 20.8 | 11.0 | 0.3 | 2.9 | 6.3 | 8.5 | 13.5 | 19.0 | 26.6 | 34.8 | 41.8 | 55.6
| 65+ | 360 | 577.4 | 22.8 | 9.9 | 0.5 | * | 9.4 | 11.1 | 15.6 | 21.5 | 28.9 | 36.7 | 40.0 | *
| All | 4022 | 5433.9 | 25.0 | 16.6 | 0.3 | 2.3 | 6.7 | 9.5 | 14.4 | 21.2 | 30.9 | 43.7 | 55.6 | 87.6
West | < 1 | 37 | 48.6 | 40.9 | 34.5 | 5.7 | * | * | 0.0 | 24.1 | 33.1 | 45.8 | 101.8 | * | *
| 1–10 | 410 | 549.2 | 40.7 | 24.0 | 1.2 | 3.6 | 10.9 | 15.6 | 23.5 | 35.4 | 52.0 | 74.4 | 89.2 | 120.9
| 11–19 | 430 | 576.5 | 19.4 | 10.8 | 0.5 | 1.3 | 5.1 | 7.5 | 11.7 | 17.9 | 24.4 | 33.2 | 39.9 | 53.5
| 20–64 | 827 | 1708.3 | 19.8 | 11.0 | 0.4 | 1.5 | 5.2 | 7.5 | 12.1 | 18.0 | 25.0 | 34.0 | 40.1 | 55.0
| 65+ | 152 | 305.1 | 22.0 | 9.2 | 0.7 | * | 8.4 | 11.6 | 16.3 | 20.5 | 26.9 | 33.3 | 38.3 | *
| All | 1856 | 3187.7 | 23.9 | 16.6 | 0.4 | 1.4 | 5.7 | 8.3 | 13.5 | 20.1 | 29.6 | 43.2 | 54.2 | 89.8
All Regions | All | 11888 | 17672.6 | 22.5 | 16.0 | 0.1 | 1.6 | 5.5 | 7.8 | 12.5 | 18.9 | 27.9 | 40.2 | 52.0 | 82.9

§ Does not include breast-fed children.

◆ Individual values nay not add to totals due to rounding.

¶ Please see Discussion (Special Problem: Infants) (page 34) regarding limitations of Tapwater estimates for infants <1 year.

* Value not reported due to insufficient number of observations.[brr] 0.0 Less than 0.05 g/kg/day.

Set E. Table 38 Tapwater Intake (g/kg/day) of Females by Broad Age Category and Geographic Region (All Seasons) ^§◆¶^

Region | Age (yr) | Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Region | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Northeast | < 1 | 48 | 56.8 | 34.6 | 45.2 | 6.5 | * | * | 0.0 | 0.7 | 25.2 | 48.1 | 66.1 | * | *
| 1–10 | 649 | 753.8 | 27.2 | 19.5 | 0.8 | 0.5 | 5.3 | 8.6 | 15.1 | 22.6 | 35.5 | 48.7 | 59.6 | 102.5
| 11–19 | 664 | 792.1 | 15.2 | 9.4 | 0.4 | 0.9 | 2.9 | 4.4 | 9.1 | 13.6 | 19.1 | 26.7 | 34.2 | 46.7
| 20–64 | 1657 | 3237.9 | 18.4 | 9.2 | 0.2 | 3.2 | 6.5 | 8.3 | 12.2 | 17.1 | 22.7 | 29.3 | 35.4 | 49.4
| 65+ | 367 | 584.2 | 19.9 | 8.7 | 0.5 | * | 8.7 | 10.6 | 13.8 | 18.4 | 24.9 | 31.1 | 35.1 | *
| All | 3385 | 5424.8 | 19.5 | 12.6 | 0.2 | 1.5 | 5.4 | 8.0 | 12.0 | 17.3 | 23.8 | 32.9 | 40.8 | 62.5
Midwest | < 1 | 48 | 55.0 | 50.2 | 42.5 | 6.1 | * | * | 1.4 | 31.1 | 43.5 | 58.8 | 75.1 | * | *
| 1–10 | 709 | 797.5 | 34.6 | 19.9 | 0.7 | 2.5 | 10.6 | 14.2 | 20.4 | 30.1 | 44.9 | 62.0 | 72.6 | 94.8
| 11–19 | 826 | 965.5 | 17.2 | 10.3 | 0.4 | 0.9 | 4.0 | 5.9 | 9.9 | 15.4 | 22.5 | 30.0 | 38.1 | 49.5
| 20–64 | 1647 | 3150.8 | 20.8 | 10.6 | 0.3 | 1.8 | 6.0 | 8.4 | 13.6 | 19.2 | 26.8 | 34.4 | 39.5 | 53.1
| 65+ | 366 | 597.2 | 22.8 | 9.0 | 0.5 | * | 10.5 | 12.4 | 16.4 | 21.7 | 27.9 | 34.2 | 37.8 | *
| All | 3596 | 5566.0 | 22.6 | 14.1 | 0.2 | 1.6 | 5.9 | 8.5 | 13.8 | 20.1 | 28.2 | 38.5 | 48.4 | 70.5
South | < 1 | 76 | 74.0 | 48.0 | 42.9 | 4.9 | * | 0.0 | 0.0 | 20.4 | 40.7 | 66.1 | 110.2 | 146.9 | *
| 1–10 | 954 | 1000.9 | 38.7 | 23.4 | 0.8 | 5.2 | 10.5 | 14.8 | 21.7 | 34.0 | 51.0 | 71.1 | 83.2 | 113.5
| 11–19 | 1013 | 1082.8 | 19.6 | 10.9 | 0.3 | 1.8 | 5.6 | 7.9 | 12.0 | 17.8 | 25.3 | 34.8 | 39.3 | 52.5
| 20–64 | 2335 | 3935.7 | 21.7 | 11.3 | 0.2 | 2.1 | 7.0 | 9.3 | 13.4 | 20.1 | 27.4 | 36.0 | 43.3 | 56.7
| 65+ | 610 | 870.7 | 22.1 | 10.7 | 0.4 | 3.9 | 8.3 | 10.1 | 14.5 | 20.0 | 27.9 | 37.0 | 42.6 | 54.0
| All | 4988 | 6964.1 | 24.1 | 15.7 | 0.2 | 2.0 | 7.0 | 9.4 | 14.0 | 20.7 | 29.7 | 42.3 | 52.2 | 81.6
West | < 1 | 31 | 39.2 | 68.5 | 63.0 | 11.3 | * | * | * | 34.9 | 52.9 | 75.6 | * | * | *
| 1–10 | 439 | 578.0 | 36.8 | 23.5 | 1.1 | 3.7 | 9.3 | 13.8 | 21.4 | 32.3 | 45.8 | 66.7 | 81.2 | 119.5
| 11–19 | 454 | 621.3 | 17.6 | 10.5 | 0.5 | 1.3 | 4.3 | 5.8 | 9.7 | 15.7 | 22.8 | 31.5 | 38.6 | 50.2
| 20–64 | 1069 | 2252.5 | 22.6 | 12.9 | 0.4 | 2.2 | 5.9 | 8.4 | 13.7 | 20.4 | 29.1 | 39.3 | 45.9 | 65.8
| 65+ | 231 | 391.9 | 23.9 | 10.0 | 0.7 | * | 10.0 | 12.6 | 16.7 | 21.8 | 29.3 | 37.5 | 45.3 | *
| All | 2224 | 3882.9 | 24.5 | 17.2 | 0.4 | 2.2 | 5.9 | 8.5 | 14.1 | 21.1 | 30.9 | 42.9 | 53.2 | 87.3
All Regions | All | 14193 | 21837.6 | 22.7 | 15.0 | 0.1 | 1.8 | 6.1 | 8.7 | 13.4 | 19.7 | 28.0 | 39.3 | 48.8 | 75.6

§ Does not include pregnant women, lactating women, or breast-fed children.

◆ Individual values may not add to totals due to rounding.

¶ Please see Discussion (Special Problem: Infants) (page 34) regarding limitations of Tapwater estimates for infants <1 year.

* Value not reported due to insufficient number of observations.

0.0 Less than 0.05 g/kg/day.

Set E. Table 39 Tapwater Intake (g/kg/day) of Both Sexes by Broad Age Category and Season (All Regions) ^§◆¶^

Season | Age (yr) | Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Season | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Spring | < 1 | 63 | 78.9 | 37.6 | 42.8 | 5.4 | * | * | 0.0 | 9.3 | 28.4 | 46.6 | 110.2 | * | *
| 1–10 | 1117 | 1511.9 | 35.9 | 21.9 | 0.7 | 2.7 | 9.1 | 13.1 | 20.3 | 31.1 | 47.3 | 65.0 | 80.1 | 104.6
| 11–19 | 1332 | 1760.4 | 18.5 | 11.0 | 0.3 | 1.3 | 4.8 | 6.8 | 11.0 | 16.4 | 23.6 | 32.7 | 39.5 | 53.5
| 20–64 | 3997 | 5258.9 | 19.5 | 10.5 | 0.2 | 2.4 | 6.0 | 8.1 | 12.1 | 18.0 | 24.8 | 33.0 | 38.1 | 53.6
| 65+ | 770 | 996.5 | 22.1 | 9.6 | 0.3 | 6.4 | 8.7 | 11.4 | 15.1 | 20.5 | 27.6 | 35.0 | 38.6 | 50.6
| All | 7279 | 9606.6 | 22.3 | 14.8 | 0.2 | 2.1 | 6.0 | 8.3 | 12.8 | 19.2 | 27.8 | 39.1 | 49.5 | 79.3
Summer | < 1 | 107 | 130.1 | 46.7 | 43.1 | 4.2 | * | 0.0 | 0.0 | 26.5 | 35.3 | 53.3 | 105.0 | 128.3 | *
| 1–10 | 1321 | 1568.1 | 38.4 | 23.6 | 0.6 | 2.5 | 9.4 | 14.1 | 21.4 | 34.5 | 50.1 | 68.6 | 82.1 | 117.7
| 11–19 | 1356 | 1672.0 | 19.8 | 11.7 | 0.3 | 1.1 | 4.7 | 7.2 | 11.6 | 17.7 | 25.8 | 36.0 | 42.8 | 56.8
| 20–64 | 2327 | 5534.3 | 20.8 | 11.4 | 0.2 | 2.4 | 6.0 | 8.4 | 13.0 | 19.1 | 26.0 | 35.3 | 42.8 | 58.4
| 65+ | 513 | 1025.1 | 23.5 | 10.7 | 0.5 | 5.1 | 9.4 | 11.2 | 15.9 | 21.6 | 28.5 | 38.3 | 43.6 | 58.8
| All | 5624 | 9929.6 | 24.0 | 16.4 | 0.2 | 1.7 | 6.2 | 9.0 | 13.8 | 20.6 | 29.4 | 43.1 | 53.6 | 81.9
Fall | < 1 | 108 | 109.7 | 50.1 | 45.9 | 4.4 | * | 0.0 | 0.0 | 23.5 | 43.5 | 64.1 | 99.3 | 126.5 | *
| 1–10 | 1619 | 1648.4 | 34.9 | 22.6 | 0.6 | 3.9 | 9.6 | 12.7 | 19.4 | 29.4 | 45.4 | 62.7 | 79.0 | 110.0
| 11–19 | 1584 | 1717.0 | 17.2 | 9.9 | 0.2 | 0.9 | 3.8 | 5.5 | 9.9 | 15.9 | 22.4 | 30.6 | 36.1 | 46.5
| 20–64 | 2692 | 5444.0 | 19.7 | 11.0 | 0.2 | 2.2 | 5.6 | 7.9 | 12.3 | 18.0 | 25.0 | 33.7 | 40.9 | 54.9
| 65+ | 632 | 1073.3 | 21.0 | 9.3 | 0.4 | 4.4 | 8.8 | 10.7 | 14.7 | 19.4 | 25.4 | 33.9 | 38.2 | 50.6
| All | 6635 | 9992.4 | 22.2 | 15.6 | 0.2 | 1.9 | 5.6 | 8.1 | 12.9 | 19.1 | 27.4 | 39.2 | 49.4 | 80.6
Winter | < 1 | 125 | 125.7 | 38.3 | 37.7 | 3.4 | * | 0.0 | 0.0 | 8.8 | 31.1 | 55.4 | 80.8 | 121.8 | *
| 1–10 | 1548 | 1625.7 | 33.1 | 23.1 | 0.6 | 1.5 | 6.3 | 10.6 | 17.7 | 28.0 | 42.5 | 61.5 | 75.5 | 119.8
| 11–19 | 1529 | 1675.6 | 17.2 | 10.1 | 0.3 | 1.2 | 4.6 | 6.4 | 10.1 | 15.2 | 21.9 | 30.7 | 37.0 | 48.3
| 20–64 | 2715 | 5507.7 | 19.5 | 10.4 | 0.2 | 1.9 | 5.7 | 7.7 | 12.3 | 17.9 | 25.3 | 33.0 | 38.3 | 52.2
| 65+ | 626 | 1047.1 | 20.6 | 9.2 | 0.4 | 2.8 | 7.0 | 9.8 | 14.5 | 19.4 | 25.8 | 32.2 | 37.0 | 48.2
| All | 6543 | 9981.8 | 21.7 | 14.9 | 0.2 | 1.5 | 5.4 | 7.8 | 12.5 | 18.6 | 27.3 | 37.6 | 46.2 | 75.6
All Seasons | All | 26081 | 39510.2 | 22.6 | 15.4 | 0.1 | 1.7 | 5.8 | 8.2 | 13.0 | 19.4 | 28.0 | 39.8 | 50.0 | 79.8

§ Does not include pregnant women, lactating women, or breast-fed children.

◆ Individual values may not add to totals due to rounding.

¶ Please see Discussion (Special Problem: Infants) (page 34) regarding limitations of Tapwater estimates for infants <1 year.

* Value not reported due to insufficient number of observations.

0.0 Less than 0.05 g/kg/day.

Set E. Table 40 Tapwater Intake (g/kg/day) of Males by Broad Age Category and Season (All Regions) ^§◆¶^

Season | Age (yr) | Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Season | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Spring | < 1 | 30 | 39.3 | 27.5 | 23.0 | 4.2 | * | * | * | 9.3 | 28.4 | 43.9 | * | * | *
| 1–10 | 581 | 795.7 | 36.6 | 22.1 | 0.9 | 2.6 | 7.9 | 12.5 | 21.2 | 31.9 | 47.9 | 67.3 | 83.9 | 102.9
| 11–19 | 657 | 883.8 | 19.7 | 11.7 | 0.5 | 1.3 | 5.1 | 7.2 | 11.6 | 17.4 | 25.5 | 34.4 | 40.8 | 56.6
| 20–64 | 1858 | 2425.7 | 18.9 | 10.4 | 0.2 | 2.4 | 5.7 | 7.6 | 11.7 | 17.3 | 24.3 | 32.0 | 37.5 | 52.7
| 65+ | 326 | 421.0 | 21.6 | 9.3 | 0.5 | * | 8.3 | 11.3 | 15.0 | 20.5 | 27.4 | 33.3 | 37.1 | *
| All | 3452 | 4565.5 | 22.5 | 15.0 | 0.3 | 2.0 | 5.9 | 8.0 | 12.6 | 19.2 | 28.4 | 40.0 | 50.6 | 82.2
Summer | < 1 | 63 | 71.6 | 41.7 | 36.2 | 4.6 | * | * | 0.0 | 26.5 | 32.2 | 51.7 | 84.0 | * | *
| 1–10 | 655 | 779.4 | 39.0 | 24.1 | 0.9 | 2.2 | 8.4 | 14.0 | 21.4 | 34.7 | 51.5 | 68.6 | 82.7 | 117.7
| 11–19 | 642 | 800.2 | 20.8 | 12.3 | 0.5 | 2.0 | 5.0 | 7.2 | 11.6 | 18.4 | 27.7 | 37.5 | 44.4 | 59.3
| 20–64 | 952 | 2284.1 | 20.1 | 11.8 | 0.4 | 2.4 | 5.5 | 7.5 | 12.3 | 17.9 | 24.8 | 35.3 | 42.5 | 62.7
| 65+ | 185 | 404.2 | 24.1 | 11.5 | 0.8 | * | 10.5 | 11.5 | 16.3 | 21.9 | 29.1 | 39.1 | 46.9 | *
| All | 2497 | 4339.5 | 24.4 | 17.1 | 0.3 | 2.1 | 5.9 | 8.2 | 13.6 | 20.4 | 30.2 | 45.0 | 56.4 | 84.0
Fall | < 1 | 47 | 50.4 | 44.0 | 38.1 | 5.6 | * | * | 2.0 | 14.7 | 35.3 | 64.1 | 106.7 | * | *
| 1–10 | 840 | 836.1 | 36.1 | 24.2 | 0.8 | 5.3 | 9.6 | 12.6 | 19.4 | 30.9 | 46.3 | 64.6 | 82.9 | 120.6
| 11–19 | 776 | 833.4 | 17.8 | 9.8 | 0.4 | 0.7 | 4.1 | 6.1 | 10.9 | 16.4 | 22.7 | 31.1 | 36.1 | 47.7
| 20–64 | 1031 | 2085.3 | 17.7 | 10.1 | 0.3 | 1.1 | 4.6 | 6.9 | 10.9 | 16.0 | 22.6 | 30.0 | 35.7 | 50.9
| 65+ | 219 | 424.1 | 20.5 | 9.3 | 0.6 | * | 8.0 | 10.3 | 14.6 | 18.8 | 25.4 | 33.2 | 37.5 | *
| All | 2913 | 4229.3 | 21.9 | 16.4 | 0.3 | 1.4 | 5.1 | 7.7 | 12.1 | 18.3 | 27.0 | 39.2 | 50.6 | 85.2
Winter | < 1 | 60 | 58.1 | 36.4 | 36.0 | 4.6 | * | * | 0.0 | 8.8 | 28.8 | 40.7 | 104.6 | * | *
| 1–10 | 778 | 812.6 | 34.5 | 23.6 | 0.8 | 1.5 | 6.8 | 11.5 | 19.3 | 29.1 | 44.1 | 64.1 | 79.2 | 124.6
| 11–19 | 769 | 845.8 | 16.9 | 9.7 | 0.3 | 1.8 | 4.5 | 6.2 | 10.5 | 15.1 | 21.3 | 29.6 | 34.3 | 48.3
| 20–64 | 1182 | 2373.0 | 18.0 | 9.3 | 0.3 | 1.9 | 5.3 | 7.2 | 11.3 | 16.9 | 23.3 | 31.0 | 35.0 | 44.5
| 65+ | 237 | 448.8 | 19.7 | 8.4 | 0.5 | * | 7.0 | 9.2 | 13.9 | 18.8 | 25.5 | 30.7 | 33.9 | *
| All | 3026 | 4538.3 | 21.2 | 15.1 | 0.3 | 1.5 | 5.2 | 7.4 | 12.0 | 18.0 | 26.4 | 36.8 | 45.7 | 79.3
All Seasons | All | 11888 | 17672.6 | 22.5 | 16.0 | 0.1 | 1.6 | 5.5 | 7.8 | 12.5 | 18.9 | 27.9 | 40.2 | 52.0 | 82.9

§ Does not include breast-fed children.

◆ Individual values may not add to totals due to rounding.

¶ Please see Discussion (Special Problem: Infants) (page 34) regarding limitations of Tapwater estimates for infants <1 year.

* Value not reported due to insufficient number of observations.

0.0 Less than 0.05 g/kg/day.

Set E. Table 41 Tapwater Intake (g/kg/day) of Females by Broad Age Category and Season (All Regions) ^§◆¶^

Season | Age (yr) | Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Season | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Spring | < 1 | 33 | 39.6 | 47.7 | 54.5 | 9.5 | * | * | * | 10.1 | 25.2 | 72.6 | * | * | *
| 1–10 | 536 | 716.2 | 35.1 | 21.7 | 0.9 | 3.2 | 10.3 | 13.8 | 19.4 | 30.1 | 46.1 | 64.1 | 74.7 | 108.1
| 11–19 | 675 | 876.6 | 17.2 | 10.2 | 0.4 | 1.5 | 4.1 | 6.0 | 10.4 | 15.2 | 22.3 | 29.3 | 36.4 | 49.7
| 20–64 | 2139 | 2833.2 | 20.0 | 10.5 | 0.2 | 2.5 | 6.5 | 8.4 | 12.7 | 18.5 | 25.3 | 33.5 | 39.2 | 54.7
| 65+ | 444 | 575.5 | 22.5 | 9.8 | 0.5 | 6.3 | 9.3 | 11.6 | 15.2 | 20.5 | 27.9 | 35.9 | 41.9 | 50.6
| All | 3827 | 5041.1 | 22.2 | 14.7 | 0.2 | 2.2 | 6.3 | 8.6 | 13.0 | 19.3 | 27.2 | 37.8 | 48.6 | 75.4
Summer | < 1 | 44 | 58.4 | 52.8 | 50.0 | 7.5 | * | * | 0.0 | 26.5 | 43.5 | 58.2 | 106.3 | * | *
| 1–10 | 666 | 788.8 | 37.8 | 23.0 | 0.9 | 2.5 | 9.5 | 14.1 | 21.3 | 34.0 | 48.6 | 69.3 | 81.2 | 118.7
| 11–19 | 714 | 871.8 | 18.9 | 11.1 | 0.4 | 1.1 | 4.3 | 6.9 | 11.6 | 16.7 | 24.4 | 33.8 | 41.1 | 51.5
| 20–64 | 1375 | 3250.3 | 21.3 | 11.1 | 0.3 | 2.6 | 6.9 | 9.4 | 13.5 | 20.0 | 26.6 | 35.3 | 42.8 | 57.0
| 65+ | 328 | 620.9 | 23.0 | 10.2 | 0.6 | * | 9.0 | 11.1 | 15.7 | 21.3 | 28.3 | 37.2 | 42.5 | *
| All | 3127 | 5590.2 | 23.8 | 15.7 | 0.3 | 1.6 | 6.8 | 9.4 | 14.0 | 20.7 | 29.0 | 41.6 | 51.2 | 79.3
Fall | < 1 | 61 | 59.3 | 55.3 | 51.3 | 6.6 | * | * | 0.0 | 35.3 | 46.8 | 66.1 | 93.0 | * | *
| 1–10 | 779 | 812.2 | 33.7 | 20.7 | 0.7 | 3.7 | 9.1 | 12.8 | 19.4 | 28.4 | 43.7 | 61.1 | 74.3 | 102.5
| 11–19 | 808 | 883.5 | 16.6 | 9.9 | 0.3 | 1.1 | 3.5 | 5.1 | 9.2 | 15.2 | 22.1 | 30.0 | 35.7 | 46.5
| 20–64 | 1661 | 3358.8 | 21.0 | 11.3 | 0.3 | 3.0 | 6.3 | 8.4 | 13.2 | 19.2 | 26.1 | 35.2 | 43.1 | 56.2
| 65+ | 413 | 649.2 | 21.3 | 9.3 | 0.5 | 4.9 | 9.2 | 11.4 | 14.9 | 19.6 | 25.2 | 34.7 | 39.7 | 51.3
| All | 3722 | 5763.0 | 22.5 | 14.9 | 0.2 | 2.4 | 6.0 | 8.4 | 13.3 | 19.6 | 27.5 | 39.2 | 48.6 | 75.5
Winter | < 1 | 65 | 67.6 | 40.0 | 39.3 | 4.9 | * | * | 0.0 | 8.8 | 34.9 | 58.8 | 80.8 | * | *
| 1–10 | 770 | 813.1 | 31.7 | 22.5 | 0.8 | 2.1 | 6.3 | 9.8 | 17.0 | 27.0 | 40.1 | 58.3 | 72.2 | 114.2
| 11–19 | 760 | 829.7 | 17.5 | 10.4 | 0.4 | 0.5 | 4.7 | 6.7 | 10.0 | 15.5 | 22.7 | 31.7 | 38.4 | 52.1
| 20–64 | 1533 | 3134.7 | 20.6 | 11.1 | 0.3 | 1.9 | 6.0 | 8.4 | 12.9 | 18.7 | 26.9 | 35.0 | 40.5 | 54.2
| 65+ | 389 | 598.3 | 21.2 | 9.7 | 0.5 | 2.7 | 7.0 | 10.9 | 14.8 | 20.0 | 26.7 | 34.2 | 37.9 | 49.7
| All | 3517 | 5443.4 | 22.1 | 14.6 | 0.2 | 1.5 | 5.6 | 8.2 | 13.0 | 19.2 | 28.0 | 38.1 | 46.5 | 71.2
All Seasons | All | 14193 | 21837.6 | 22.7 | 15.0 | 0.1 | 1.8 | 6.1 | 8.7 | 13.4 | 19.7 | 28.0 | 39.3 | 48.8 | 75.6

§ Does not include pregnant women, lactating women, or breast-fed children.

◆ Individual values may not add to totals due to rounding.

¶ Please see Discussion (Special Problem: Infants) (page 34) regarding limitations of Tapwater estimates for infants <1 year.

* Value not reported due to insufficient number of observations.

0.0 Less than 0.05 g/kg/day.

### F TAPWATER INTAKE (As Percent of Total Water Intake)

Set F. Table 42 Tapwater Intake (as Percent of Total Water Intake) by Broad Age Category and Sex (All Regions, All Seasons) ^§◆¶^

Sex | Age (yr) | Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Sex | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Both Sexes | < 1 | 403 | 444.3 | 26 | 20 | 1 | 0 | 0 | 0 | 12 | 22 | 37 | 55 | 62 | 82
| 1–10 | 5605 | 6354.1 | 45 | 16 | 0 | 6 | 19 | 24 | 34 | 45 | 57 | 67 | 72 | 81
| 11–19 | 5801 | 6824.9 | 47 | 17 | 0 | 6 | 18 | 24 | 35 | 47 | 59 | 69 | 74 | 83
| 20–64 | 11731 | 21744.9 | 59 | 17 | 0 | 12 | 27 | 35 | 49 | 61 | 72 | 79 | 83 | 90
| 65+ | 2541 | 4142.0 | 65 | 14 | 0 | 25 | 41 | 47 | 58 | 67 | 74 | 81 | 84 | 90
| All | 26081 | 39510.2 | 55 | 18 | 0 | 8 | 22 | 30 | 43 | 57 | 69 | 77 | 82 | 89
Males | < 1 | 200 | 219.4 | 24 | 19 | 1 | * | 0 | 0 | 10 | 22 | 35 | 51 | 59 | *
| 1–10 | 2854 | 3223.8 | 46 | 17 | 0 | 6 | 19 | 24 | 34 | 46 | 57 | 68 | 73 | 82
| 11–19 | 2844 | 3363.2 | 46 | 17 | 0 | 6 | 18 | 24 | 34 | 46 | 58 | 68 | 73 | 81
| 20–64 | 5023 | 9168.1 | 56 | 17 | 0 | 11 | 24 | 32 | 45 | 58 | 69 | 77 | 81 | 88
| 65+ | 967 | 1698.1 | 64 | 14 | 0 | 24 | 38 | 46 | 56 | 65 | 74 | 80 | 84 | 89
| All | 11888 | 17672.6 | 53 | 18 | 0 | 7 | 21 | 28 | 40 | 54 | 66 | 75 | 80 | 87
Females | < 1 | 203 | 225.0 | 27 | 21 | 1 | * | 0 | 0 | 12 | 22 | 41 | 57 | 66 | *
| 1–10 | 2751 | 3130.2 | 45 | 16 | 0 | 6 | 19 | 24 | 34 | 45 | 56 | 66 | 71 | 81
| 11–19 | 2957 | 3461.7 | 48 | 17 | 0 | 6 | 19 | 25 | 36 | 48 | 60 | 70 | 75 | 84
| 20–64 | 6708 | 12576.8 | 61 | 17 | 0 | 12 | 30 | 39 | 52 | 63 | 73 | 81 | 85 | 91
| 65+ | 1574 | 2443.9 | 66 | 13 | 0 | 27 | 42 | 49 | 59 | 68 | 75 | 82 | 85 | 90
| All | 14193 | 21837.6 | 57 | 18 | 0 | 8 | 23 | 32 | 45 | 59 | 71 | 79 | 83 | 90

§ Does not include pregnant women, lactating women, or breast-fed children.

◆ Individual values may not add to totals due to rounding.

¶ Please see Discussion (Special Problem: Infants) (page 34) regarding limitations of Tapwater estimates for infants <1 year.

* Value not reported due to insufficient number of observations.

0 Less than 0.5 percent.

Set F. Table 43 Tapwater Intake (as Percent of Total Water Intake) by Fine Age Category and Sex (All Regions, All Seasons) ^§◆¶^

Sex | Age (yr) | Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Sex | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Both Sexes | < 0.5 | 182 | 201.2 | 26 | 22 | 2 | * | 0 | 0 | 11 | 22 | 39 | 57 | 65 | *
| 0.5–0.9 | 221 | 243.2 | 25 | 18 | 1 | * | 0 | 0 | 12 | 22 | 36 | 49 | 58 | *
| 1– 3 | 1498 | 1687.7 | 46 | 18 | 0 | 3 | 16 | 22 | 34 | 46 | 58 | 69 | 74 | 82
| 4– 6 | 1702 | 1923.9 | 47 | 16 | 0 | 9 | 19 | 26 | 36 | 47 | 58 | 69 | 73 | 82
| 7–10 | 2405 | 2742.4 | 44 | 16 | 0 | 7 | 19 | 24 | 34 | 44 | 55 | 65 | 70 | 79
| 11–14 | 2803 | 3146.9 | 46 | 16 | 0 | 7 | 20 | 25 | 35 | 46 | 58 | 68 | 73 | 81
| 15–19 | 2998 | 3677.9 | 47 | 18 | 0 | 4 | 18 | 23 | 35 | 48 | 59 | 70 | 76 | 84
| 20–44 | 7171 | 13444.5 | 56 | 18 | 0 | 9 | 23 | 31 | 45 | 58 | 69 | 78 | 83 | 90
| 45–64 | 4560 | 8300.4 | 64 | 14 | 0 | 22 | 38 | 45 | 56 | 66 | 75 | 81 | 85 | 90
| 65–74 | 1663 | 2740.2 | 65 | 14 | 0 | 24 | 42 | 48 | 58 | 67 | 75 | 81 | 85 | 90
| 75+ | 878 | 1401.8 | 65 | 13 | 0 | 28 | 41 | 47 | 56 | 66 | 74 | 80 | 84 | 90
| All | 26081 | 39510.2 | 55 | 18 | 0 | 8 | 22 | 30 | 43 | 57 | 69 | 77 | 82 | 89
Males | < 0.5 | 87 | 96.4 | 24 | 21 | 2 | * | 0 | 0 | 7 | 21 | 36 | 57 | 60 | *
| 0.5–0.9 | 113 | 122.9 | 25 | 17 | 2 | * | 0 | 2 | 13 | 23 | 34 | 49 | 56 | *
| 1– 3 | 775 | 879.6 | 46 | 18 | 1 | 2 | 18 | 23 | 35 | 46 | 58 | 70 | 74 | 83
| 4– 6 | 883 | 991.4 | 48 | 16 | 1 | 9 | 20 | 27 | 37 | 49 | 59 | 70 | 75 | 82
| 7–10 | 1196 | 1352.9 | 44 | 16 | 0 | 6 | 19 | 24 | 33 | 43 | 56 | 65 | 70 | 78
| 11–14 | 1395 | 1571.8 | 45 | 16 | 0 | 7 | 18 | 25 | 35 | 46 | 57 | 67 | 72 | 80
| 15–19 | 1449 | 1791.4 | 46 | 17 | 0 | 4 | 18 | 23 | 34 | 47 | 58 | 69 | 74 | 83
| 20–44 | 3146 | 5702.7 | 53 | 18 | 0 | 8 | 21 | 28 | 41 | 55 | 66 | 74 | 79 | 87
| 45–64 | 1877 | 3465.4 | 62 | 15 | 0 | 16 | 35 | 42 | 53 | 64 | 72 | 79 | 82 | 88
| 65–74 | 656 | 1172.3 | 64 | 14 | 1 | 23 | 40 | 47 | 56 | 65 | 73 | 81 | 84 | 89
| 75+ | 311 | 525.8 | 64 | 14 | 1 | * | 38 | 45 | 55 | 66 | 74 | 80 | 85 | *
| All | 11888 | 17672.6 | 53 | 18 | 0 | 7 | 21 | 28 | 40 | 54 | 66 | 75 | 80 | 87
Females | < 0.5 | 95 | 104.7 | 28 | 22 | 2 | * | 0 | 0 | 14 | 22 | 47 | 60 | 66 | *
| 0.5–0.9 | 108 | 120.2 | 26 | 19 | 2 | * | 0 | 0 | 12 | 22 | 39 | 51 | 60 | *
| 1– 3 | 723 | 808.2 | 45 | 17 | 1 | 5 | 15 | 22 | 33 | 45 | 57 | 68 | 74 | 82
| 4– 6 | 819 | 932.5 | 46 | 16 | 1 | 8 | 19 | 25 | 35 | 45 | 57 | 67 | 72 | 80
| 7–10 | 1209 | 1389.5 | 44 | 15 | 0 | 7 | 20 | 25 | 34 | 45 | 55 | 64 | 68 | 79
| 11–14 | 1408 | 1575.1 | 47 | 16 | 0 | 7 | 20 | 26 | 36 | 48 | 59 | 68 | 74 | 81
| 15–19 | 1549 | 1886.5 | 48 | 18 | 0 | 4 | 18 | 24 | 36 | 49 | 61 | 71 | 77 | 85
| 20–44 | 4025 | 7741.7 | 58 | 18 | 0 | 9 | 27 | 35 | 47 | 60 | 71 | 80 | 84 | 91
| 45–64 | 2683 | 4835.1 | 66 | 14 | 0 | 24 | 41 | 48 | 58 | 68 | 76 | 82 | 86 | 91
| 65–74 | 1007 | 1567.9 | 66 | 14 | 0 | 27 | 42 | 49 | 60 | 68 | 76 | 82 | 85 | 90
| 75+ | 567 | 876.0 | 65 | 13 | 1 | 28 | 43 | 47 | 58 | 66 | 74 | 81 | 83 | 90
| All | 14193 | 21837.6 | 57 | 18 | 0 | 8 | 23 | 32 | 45 | 59 | 71 | 79 | 83 | 90

§ Does not include pregnant women, lactating women, or breast-fed children.

◆ Individual values may not add to totals due to rounding.

¶ Please see Discussion (Special Problem: Infants) (page 34) regarding limitations of Tapwater estimates for infants <1 year.

* Value not reported due to insufficient number of observations.

0 Less than 0.5 percent.

Set F. Table 44 Tapwater Intake (as Percent of Total Water Intake) of Pregnant Women, Lactating Women, and Breast-fed Children (All Regions, All Seasons) ^¶^

| Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
| Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 5 | 10 | 25 | 50 | 75 | 90 | 95
Pregnant women | 188 | 327.5 | 54.1 | 18.2 | 1.3 | 21.2 | 27.9 | 42.9 | 54.8 | 67.6 | 76.6 | 83.2
Lactating women | 77 | 151.2 | 57.0 | 15.8 | 1.8 | 27.4 | 38.0 | 49.5 | 58.1 | 65.9 | 76.4 | 80.5
Breast-fed children
Both sexes
All ages | 100 | 121.0 | 32.1 | 34.7 | 3.5 | 0.0 | 0.0 | 0.0 | 22.3 | 55.1 | 98.2 | 100.0
< 0.5 yr | 62 | 74.4 | 29.0 | 38.5 | 4.9 | * | 0.0 | 0.0 | 0.0 | 55.0 | 100.0 | *
≥ 0.5 yr | 38 | 46.6 | 37.1 | 27.3 | 4.4 | * | 0.0 | 15.2 | 33.6 | 57.2 | 80.8 | *
Males
All ages | 42 | 49.4 | 25.5 | 31.0 | 4.8 | * | 0.0 | 0.0 | 8.9 | 48.6 | 57.9 | *
< 0.5 yr | 28 | 34.0 | 19.5 | 31.1 | 5.9 | * | * | 0.0 | 0.0 | 37.8 | * | *
≥ 0.5 yr | 14 | 15.5 | * | * | * | * | * | 14.7 | 40.2 | 55.1 | * | *
Females
All ages | 58 | 71.6 | 36.7 | 36.6 | 4.8 | * | 0.0 | 0.0 | 23.9 | 66.8 | 99.9 | *
< 0.5 yr | 34 | 40.5 | 37.1 | 42.5 | 7.3 | * | * | 0.0 | 21.3 | 73.5 | * | *
≥ 0.5 yr | 24 | 31.1 | * | * | * | * | * | 15.2 | 29.6 | 58.1 | * | *

¶ Please see Discussion (Special Problem: Infants) (page 34) regarding limitations of Tapwater estimates for infants <1 year.

* Value not reported due to insufficient number of observations.

0.0 Less than 0.05 percent.

Set F. Table 45 Tapwater Intake (as Percent of Total Water Intake) of Both Sexes by Broad Age Category and Geographic Region (All Seasons) ^§◆¶^

Region | Age (yr) | Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Region | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Northeast | < 1 | 84 | 95.7 | 21 | 19 | 2 | * | 0 | 0 | 7 | 19 | 30 | 48 | 57 | *
| 1–10 | 1323 | 1519.2 | 38 | 16 | 0 | 2 | 12 | 18 | 27 | 37 | 48 | 58 | 66 | 76
| 11–19 | 1324 | 1565.0 | 42 | 17 | 0 | 2 | 14 | 20 | 30 | 42 | 53 | 64 | 70 | 81
| 20–64 | 2883 | 5548.0 | 56 | 17 | 0 | 11 | 25 | 33 | 46 | 57 | 68 | 75 | 79 | 87
| 65+ | 584 | 959.4 | 62 | 13 | 1 | 24 | 37 | 45 | 54 | 63 | 71 | 77 | 82 | 90
| All | 6198 | 9687.3 | 51 | 18 | 0 | 5 | 18 | 26 | 38 | 53 | 65 | 73 | 78 | 86
Midwest | < 1 | 101 | 114.5 | 24 | 18 | 2 | * | 0 | 0 | 14 | 21 | 34 | 53 | 57 | *
| 1–10 | 1505 | 1700.8 | 46 | 15 | 0 | 8 | 21 | 27 | 36 | 45 | 56 | 66 | 72 | 80
| 11–19 | 1611 | 1908.0 | 46 | 17 | 0 | 6 | 20 | 24 | 34 | 46 | 57 | 68 | 74 | 82
| 20–64 | 2972 | 5593.4 | 59 | 17 | 0 | 12 | 27 | 34 | 49 | 62 | 72 | 80 | 84 | 90
| 65+ | 604 | 1037.5 | 66 | 13 | 1 | 23 | 44 | 48 | 59 | 68 | 75 | 81 | 84 | 88
| All | 6793 | 10354.2 | 55 | 18 | 0 | 8 | 22 | 30 | 42 | 56 | 69 | 77 | 82 | 88
South | < 1 | 150 | 146.3 | 27 | 20 | 2 | * | 0 | 0 | 13 | 24 | 39 | 56 | 65 | *
| 1–10 | 1928 | 2006.8 | 50 | 16 | 0 | 7 | 23 | 30 | 40 | 51 | 61 | 70 | 75 | 84
| 11–19 | 1982 | 2154.1 | 52 | 16 | 0 | 8 | 23 | 30 | 41 | 53 | 63 | 72 | 78 | 87
| 20–64 | 3980 | 6642.8 | 63 | 16 | 0 | 14 | 31 | 40 | 54 | 65 | 74 | 82 | 85 | 91
| 65+ | 970 | 1448.1 | 67 | 14 | 0 | 27 | 42 | 48 | 60 | 69 | 76 | 83 | 86 | 93
| All | 9010 | 12398.1 | 59 | 17 | 0 | 9 | 27 | 35 | 48 | 61 | 72 | 80 | 84 | 90
West | < 1 | 68 | 87.7 | 31 | 22 | 3 | * | * | 0 | 17 | 26 | 44 | 62 | * | *
| 1–10 | 849 | 1127.2 | 46 | 16 | 1 | 11 | 20 | 25 | 36 | 47 | 57 | 67 | 72 | 79
| 11–19 | 884 | 1197.8 | 46 | 17 | 1 | 5 | 18 | 24 | 34 | 47 | 58 | 68 | 74 | 83
| 20–64 | 1896 | 3960.7 | 58 | 18 | 0 | 8 | 27 | 34 | 47 | 60 | 71 | 80 | 84 | 90
| 65+ | 383 | 697.0 | 65 | 13 | 1 | 26 | 42 | 47 | 58 | 66 | 74 | 81 | 83 | 88
| All | 4080 | 7070.4 | 55 | 18 | 0 | 8 | 22 | 29 | 43 | 56 | 68 | 77 | 82 | 88
All Regions | All | 26081 | 39510.2 | 55 | 18 | 0 | 8 | 22 | 30 | 43 | 57 | 69 | 77 | 82 | 89

§ Does not include pregnant women, lactating women, or breast-fed children.

◆ Individual values may not add to totals due to rounding.

¶ Please see Discussion (Special Problem: Infants) (page 34) regarding limitations of Tapwater estimates for infants <1 year.

* Value not reported due to insufficient number of observations.

0 Less than 0.5 percent.

Set F. Table 46 Tapwater Intake (as Percent of Total Water Intake) of Both Sexes by Broad Age Category and Season (All Regions) ^§◆¶^

Season | Age (yr) | Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Season | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Spring | < 1 | 63 | 78.9 | 23 | 20 | 3 | * | * | 0 | 7 | 19 | 36 | 51 | * | *
| 1–10 | 1117 | 1511.9 | 47 | 16 | 0 | 6 | 19 | 25 | 35 | 47 | 58 | 68 | 73 | 81
| 11–19 | 1332 | 1760.4 | 48 | 17 | 0 | 6 | 19 | 25 | 35 | 48 | 60 | 69 | 75 | 84
| 20–64 | 3997 | 5258.9 | 59 | 17 | 0 | 13 | 28 | 35 | 48 | 61 | 71 | 79 | 83 | 90
| 65+ | 770 | 996.5 | 65 | 13 | 0 | 29 | 42 | 48 | 57 | 67 | 75 | 81 | 84 | 88
| All | 7279 | 9606.6 | 55 | 18 | 0 | 8 | 23 | 30 | 43 | 57 | 69 | 77 | 81 | 88
Summer | < 1 | 107 | 130.1 | 27 | 19 | 2 | * | 0 | 0 | 16 | 24 | 39 | 56 | 66 | *
| 1–10 | 1321 | 1568.1 | 48 | 17 | 0 | 7 | 19 | 25 | 37 | 48 | 60 | 69 | 74 | 82
| 11–19 | 1356 | 1672.0 | 49 | 17 | 0 | 6 | 20 | 26 | 37 | 50 | 61 | 71 | 76 | 82
| 20–64 | 2327 | 5534.3 | 59 | 17 | 0 | 11 | 28 | 36 | 50 | 61 | 72 | 80 | 83 | 90
| 65+ | 513 | 1025.1 | 65 | 14 | 1 | 24 | 42 | 47 | 57 | 67 | 74 | 81 | 84 | 93
| All | 5624 | 9929.6 | 56 | 18 | 0 | 8 | 23 | 31 | 44 | 58 | 69 | 78 | 82 | 89
Fall | < 1 | 108 | 109.7 | 27 | 18 | 2 | * | 0 | 0 | 17 | 22 | 42 | 56 | 59 | *
| 1–10 | 1619 | 1648.4 | 45 | 16 | 0 | 8 | 20 | 25 | 34 | 44 | 55 | 66 | 71 | 79
| 11–19 | 1584 | 1717.0 | 45 | 17 | 0 | 5 | 16 | 22 | 34 | 46 | 56 | 67 | 71 | 81
| 20–64 | 2692 | 5444.0 | 59 | 17 | 0 | 11 | 27 | 35 | 49 | 61 | 72 | 80 | 84 | 90
| 65+ | 632 | 1073.3 | 65 | 14 | 1 | 28 | 41 | 47 | 57 | 66 | 75 | 81 | 85 | 88
| All | 6635 | 9992.4 | 55 | 18 | 0 | 8 | 22 | 29 | 42 | 56 | 69 | 78 | 82 | 88
Winter | < 1 | 125 | 125.7 | 24 | 22 | 2 | * | 0 | 0 | 8 | 21 | 34 | 52 | 70 | *
| 1–10 | 1548 | 1625.7 | 43 | 16 | 0 | 4 | 15 | 22 | 32 | 43 | 54 | 63 | 70 | 81
| 11–19 | 1529 | 1675.6 | 46 | 17 | 0 | 6 | 19 | 25 | 35 | 46 | 57 | 68 | 74 | 85
| 20–64 | 2715 | 5507.7 | 59 | 17 | 0 | 11 | 27 | 35 | 49 | 61 | 72 | 79 | 84 | 90
| 65+ | 626 | 1047.1 | 65 | 14 | 1 | 22 | 36 | 47 | 58 | 67 | 74 | 81 | 85 | 89
| All | 6543 | 9981.8 | 55 | 19 | 0 | 6 | 21 | 29 | 42 | 56 | 69 | 77 | 82 | 89
All Seasons | All | 26081 | 39510.2 | 55 | 18 | 0 | 8 | 22 | 30 | 43 | 57 | 69 | 77 | 82 | 89

§ Does not include pregnant women, lactating women, or breast-fed children.

◆ Individual values may not add to totals due to rounding.

¶ Please see Discussion (Special Problem: Infants) (page 34) regarding limitations of Tapwater estimates for infants <1 year.

* Value not reported due to insufficient number of observations.

0 Less than 0.5 percent.

### G GENERAL DIETARY SOURCES OF TOTAL WATER

Set G. Table 47 General Dietary Sources of Total Water by Broad Age Category (Both Sexes, All Regions, All Seasons) ^§◆^

| Number of Observations | | | g/day | | | | | | | | % of Total g/day
Age (yr) | Actual Count | Weighted Count | Source | Mean | Standard Deviation | 5 | 25 | 50 | 75 | 95 | 99 | Mean | Standard Deviation | 5 | 25 | 50 | 75 | 95 | 99
< 1 | 403 | 444.3 | Food^¶^ | 250 | 198 | 0 | 72 | 236 | 381 | 633 | 843 | 21 | 16 | 0 | 8 | 21 | 32 | 50 | 60
| | | Drinking Water | 197 | 186 | 0 | 0 | 240 | 240 | 480 | 880 | 16 | 14 | 0 | 0 | 17 | 24 | 39 | 60
| | | Other Beverages | 701 | 235 | 333 | 558 | 693 | 839 | 1085 | 1332 | 63 | 19 | 33 | 51 | 63 | 76 | 97 | 100
| | | All Sources | 1148 | 332 | 631 | 920 | 1120 | 1339 | 1727 | 2060 | 100
1–10 | 5605 | 6354.1 | Food^¶^ | 409 | 175 | 175 | 283 | 384 | 506 | 727 | 924 | 27 | 10 | 13 | 20 | 26 | 33 | 44 | 53
| | | Drinking Water | 505 | 354 | 0 | 240 | 480 | 720 | 1200 | 1600 | 30 | 16 | 0 | 20 | 30 | 41 | 56 | 68
| | | Other Beverages | 645 | 247 | 283 | 483 | 630 | 784 | 1083 | 1372 | 43 | 14 | 21 | 33 | 42 | 52 | 66 | 77
| | | All Sources | 1559 | 507 | 838 | 1210 | 1497 | 1843 | 2507 | 3013 | 100
11–19 | 5801 | 6824.9 | Food^¶^ | 515 | 230 | 204 | 349 | 487 | 638 | 933 | 1197 | 27 | 10 | 12 | 20 | 26 | 33 | 44 | 54
| | | Drinking Water | 664 | 483 | 0 | 320 | 560 | 880 | 1600 | 2160 | 31 | 17 | 0 | 20 | 31 | 42 | 60 | 73
| | | Other Beverages | 809 | 382 | 289 | 566 | 756 | 984 | 1490 | 2105 | 42 | 15 | 18 | 32 | 41 | 51 | 67 | 78
| | | All Sources | 1989 | 719 | 1025 | 1489 | 1874 | 2369 | 3336 | 4251 | 100
20–64 | 11731 | 21744.9 | Food^¶^ | 545 | 239 | 223 | 375 | 509 | 678 | 992 | 1254 | 26 | 10 | 11 | 18 | 24 | 32 | 44 | 55
| | | Drinking Water | 674 | 555 | 0 | 320 | 560 | 960 | 1760 | 2560 | 28 | 17 | 0 | 16 | 28 | 40 | 59 | 71
| | | Other Beverages | 1024 | 539 | 358 | 668 | 925 | 1267 | 2001 | 2912 | 46 | 17 | 20 | 35 | 46 | 57 | 75 | 84
| | | All Sources | 2243 | 839 | 1133 | 1665 | 2109 | 2663 | 3793 | 5081 | 100
65+ | 2541 | 4142.0 | Food^¶^ | 575 | 243 | 238 | 406 | 542 | 711 | 1028 | 1273 | 27 | 10 | 12 | 20 | 26 | 33 | 45 | 54
| | | Drinking Water | 776 | 554 | 0 | 400 | 720 | 1040 | 1920 | 2400 | 33 | 17 | 0 | 22 | 33 | 45 | 61 | 74
| | | Other Beverages | 849 | 381 | 310 | 604 | 807 | 1032 | 1523 | 2037 | 40 | 15 | 16 | 30 | 39 | 49 | 66 | 78
| | | All Sources | 2199 | 728 | 1196 | 1700 | 2109 | 2616 | 3482 | 4370 | 100
All | 26081 | 39510.2 | Food^¶^ | 517 | 236 | 201 | 351 | 483 | 647 | 955 | 1220 | 26 | 10 | 12 | 19 | 25 | 32 | 44 | 54
| | | Drinking Water | 651 | 520 | 0 | 240 | 560 | 880 | 1600 | 2400 | 30 | 17 | 0 | 17 | 29 | 41 | 59 | 71
| | | Other Beverages | 904 | 481 | 318 | 596 | 811 | 1110 | 1774 | 2612 | 44 | 16 | 19 | 33 | 44 | 55 | 73 | 83
| | | All Sources | 2072 | 803 | 1012 | 1511 | 1950 | 2485 | 3550 | 4655 | 100

§ Does not include pregnant women, lactating women, or breast-fed children.

◆ Individual values may not add to totals due to rounding.

¶ Food category includes soups.

0 Less than 0.5 g/day or 0.5 percent.

Set G. Table 48 General Dietary Sources of Total Water of Pregnant Women, Lactating Women, and Breast-fed Children (All Regions, All Seasons) ^§^

| Number of Observations | | | g/day | | | | | | | % of Total g/day
| Actual Count | Weighted Count | Source | Mean | Standard Deviation | 5 | 25 | 50 | 75 | 95 | Mean | Standard Deviation | 5 | 25 | 50 | 75 | 95
Pregnant women | 188 | 327.5 | Food^◆^ | 483 | 214 | 191 | 323 | 455 | 612 | 867 | 25 | ii | 9 | 17 | 24 | 31 | 41
| | | Drinking Water | 695 | 525 | 0 | 320 | 640 | 960 | 1760 | 32 | 19 | 0 | 18 | 30 | 43 | 66
| | | Other Beverages | 897 | 497 | 274 | 546 | 820 | 1130 | 1818 | 44 | 17 | 17 | 32 | 44 | 55 | 70
| | | All Sources | 2076 | 743 | 1085 | 1553 | 1928 | 2444 | 3475 | 100
Lactating women | 77 | 151.2 | Food^◆^ | 558 | 268 | 254 | 382 | 499 | 678 | 1175 | 25 | 9 | 12 | 19 | 24 | 30 | 46
| | | Drinking Water | 677 | 492 | 0 | 240 | 560 | 1040 | 1600 | 29 | 18 | 0 | 13 | 29 | 44 | 55
| | | Other Beverages | 1008 | 512 | 307 | 719 | 913 | 1215 | 1885 | 46 | 18 | 16 | 35 | 47 | 58 | 71
| | | All Sources | 2243 | 658 | 1185 | 1833 | 2164 | 2658 | 3353 | 100
Breast-fed children^¶^ | 100 | 121.0 | Food^◆^ | 129 | 147 | 0 | 0 | 83 | 224 | 429 | 36 | 31 | 0 | 10 | 30 | 56 | 100
Breast-fed children^¶^ | | | Drinking Water | 110 | 140 | 0 | 0 | 0 | 240 | 320 | 28 | 33 | 0 | 0 | 21 | 43 | 100
| | | Other Beverages | 162 | 205 | 0 | 0 | 78 | 254 | 555 | 37 | 32 | 0 | 0 | 31 | 59 | 99
| | | All Sources | 402 | 352 | 0 | 69 | 315 | 633 | 1023 | 100

§ Individual values may not add to totals due to rounding.

◆ Food category includes soups.

¶ Total water intake does not include the contribution of breast milk

0 Less than 0.5 g/day or 0.5 percent.

### H DIETARY SOURCES OF TOTAL WATER

Set H. Table 49 Dietary Sources of Total Water of Males and Females (Ages Under 1 Year) (All Regions, All Seasons) ^§◆^

| | g/day | | | | | | | | % of Total g/day
Sources of Total Water | | Mean^¶^ | Standard Deviation | 5 | 25 | 50 | 75 | 95 | 99 | Mean | Standard Deviation | 5 | 25 | 50 | 75 | 95 | 99
1. | Drinking water | 197 | 186 | 0 | 0 | 240 | 240 | 480 | 880 | 16 | 14 | 0 | 0 | 17 | 24 | 39 | 60
2. | Baby formula | 334 | 375 | 0 | 0 | 0 | 666 | 962 | 1135 | 33 | 36 | 0 | 0 | 0 | 69 | 94 | 100
3. | Milk | 301 | 341 | 0 | 0 | 181 | 579 | 868 | 1141 | 25 | 27 | 0 | 0 | 15 | 48 | 70 | 88
4. | Milk drinks | 0 | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
5. | Other dairy products | 4 | 16 | 0 | 0 | 0 | 0 | 28 | 66 | 0 | 1 | 0 | 0 | 0 | 0 | 2 | 6
6. | Meat, poultry, fish and mixtures thereof | 7 | 20 | 0 | 0 | 0 | 0 | 47 | 82 | 1 | 2 | 0 | 0 | 0 | 0 | 4 | 8
7. | Eggs and egg dishes | 3 | 10 | 0 | 0 | 0 | 0 | 33 | 49 | 0 | 1 | 0 | 0 | 0 | 0 | 2 | 4
8. | Legumes, nuts and seeds | 1 | 7 | 0 | 0 | 0 | 0 | 4 | 30 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 4
9. | Grains and grain products | 22 | 53 | 0 | 0 | 0 | 10 | 149 | 245 | 2 | 4 | 0 | 0 | 0 | 1 | 11 | 19
10. | Citrus Juices | 11 | 35 | 0 | 0 | 0 | 0 | 91 | 146 | 1 | 3 | 0 | 0 | 0 | 0 | 7 | 13
11. | Non-citrus fruit juices and tomato juice | 11 | 40 | 0 | 0 | 0 | 0 | 72 | 217 | 1 | 3 | 0 | 0 | 0 | 0 | 7 | 18
12. | Fruits | 12 | 36 | 0 | 0 | 0 | 0 | 90 | 185 | 1 | 3 | 0 | 0 | 0 | 0 | 8 | 14
13. | Potatoes | 8 | 25 | 0 | 0 | 0 | 0 | 53 | 147 | 1 | 2 | 0 | 0 | 0 | 0 | 5 | 11
14. | Vegetables and tomatoes | 12 | 36 | 0 | 0 | 0 | 0 | 75 | 160 | 1 | 3 | 0 | 0 | 0 | 0 | 6 | 13
15. | Fats, oils and dressings | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
16. | Sugars and sweets | 3 | 15 | 0 | 0 | 0 | 0 | 17 | 70 | 0 | 1 | 0 | 0 | 0 | 0 | 1 | 6
17. | Tea | 7 | 43 | 0 | 0 | 0 | 0 | 10 | 317 | 1 | 5 | 0 | 0 | 0 | 0 | 1 | 32
18. | Coffee | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
19. | Coffee substitutes | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
20. | Carbonated soft drinks, regular | 4 | 25 | 0 | 0 | 0 | 0 | 0 | 186 | 0 | 2 | 0 | 0 | 0 | 0 | 0 | 16
21. | Carbonated soft drinks, low calorie | 0 | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
22. | Non-carbonated soft drinks, regular | 8 | 44 | 0 | 0 | 0 | 0 | 55 | 200 | 1 | 3 | 0 | 0 | 0 | 0 | 4 | 13
23. | Non-carbonated soft drinks, low calorie | 2 | 20 | 0 | 0 | 0 | 0 | 0 | 57 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 4
24. | Beer | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
25. | Wine | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
26. | Spirits, liqueurs, and mixed drinks | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
27. | Baby fruit juice | 23 | 48 | 0 | 0 | 0 | 18 | 124 | 219 | 2 | 4 | 0 | 0 | 0 | 1 | 12 | 16
28. | Baby food (excluding baby fruit Juice) | 177 | 177 | 0 | 3 | 138 | 294 | 490 | 674 | 15 | 14 | 0 | 0 | 12 | 25 | 41 | 52
| All Sources | 1148 | 332 | 631 | 920 | 1120 | 1339 | 1727 | 2060 | 100

§ Does not include breast-fed children.

◆ Individual values may not add to totals due to rounding.

¶ Actual number of observations = 403; weighted number of observations = 444.3.

0 Less than 0.3 g/day or less than 0.5 percent.

Set H. Table 50 Dietary Sources of Total Water of Males and Females (Ages 1-10 Years) (All Regions, All Seasons) ^§◆^

| | g/day | | | | | | | | % of Total g/day
Sources of Total Water | | Mean^¶^ | Standard Deviation | 5 | 25 | 50 | 75 | 95 | 99 | Mean | Standard Deviation | 5 | 25 | 50 | 75 | 95 | 99
1. | Drinking water | 505 | 354 | 0 | 240 | 480 | 720 | 1200 | 1600 | 30 | 16 | 0 | 20 | 30 | 41 | 56 | 68
2. | Baby formula | 2 | 30 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 2 | 0 | 0 | 0 | 0 | 0 | 0
3. | Milk | 354 | 216 | 45 | 196 | 325 | 481 | 749 | 963 | 23 | 13 | 3 | 14 | 22 | 32 | 47 | 61
4. | Milk drinks | 24 | 60 | 0 | 0 | 0 | 0 | 137 | 274 | 2 | 4 | 0 | 0 | 0 | 0 | 10 | 19
5. | Other dairy products | 21 | 30 | 0 | 0 | 9 | 31 | 79 | 130 | 1 | 2 | 0 | 0 | 1 | 2 | 5 | 8
6. | Meat, poultry, fish and mixtures thereof | 81 | 53 | 18 | 44 | 69 | 104 | 181 | 258 | 5 | 4 | 1 | 3 | 5 | 7 | 12 | 17
7. | Eggs and egg dishes | 14 | 18 | 0 | 0 | 10 | 22 | 49 | 80 | 1 | 1 | 0 | 0 | 1 | 1 | 3 | 6
8. | Legumes, nuts and seeds | 12 | 26 | 0 | 0 | 0 | 11 | 61 | 125 | 1 | 2 | 0 | 0 | 0 | 1 | 4 | 8
9. | Grains and grain products | 106 | 84 | 16 | 46 | 83 | 142 | 265 | 387 | 7 | 5 | 1 | 3 | 6 | 9 | 18 | 25
10. | Citrus Juices | 50 | 75 | 0 | 0 | 0 | 73 | 201 | 292 | 3 | 5 | 0 | 0 | 0 | 6 | 13 | 21
11. | Non-citrus fruit juices and tomato juice | 16 | 54 | 0 | 0 | 0 | 0 | 109 | 246 | 1 | 4 | 0 | 0 | 0 | 0 | 8 | 20
12. | Fruits | 58 | 70 | 0 | 0 | 36 | 91 | 191 | 310 | 4 | 4 | 0 | 0 | 2 | 6 | 12 | 20
13. | Potatoes | 32 | 37 | 0 | 4 | 23 | 49 | 105 | 158 | 2 | 2 | 0 | 0 | 1 | 3 | 7 | 10
14. | Vegetables and tomatoes | 69 | 64 | 0 | 22 | 52 | 97 | 192 | 297 | 4 | 4 | 0 | 2 | 3 | 6 | 12 | 18
15. | Fats, oils and dressings | 2 | 3 | 0 | 0 | 1 | 2 | 6 | 12 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1
16. | Sugars and sweets | 11 | 23 | 0 | 0 | 1 | 9 | 67 | 106 | 1 | 1 | 0 | 0 | 0 | 1 | 4 | 7
17. | Tea | 42 | 101 | 0 | 0 | 0 | 0 | 238 | 429 | 3 | 6 | 0 | 0 | 0 | 0 | 17 | 29
18. | Coffee | 2 | 18 | 0 | 0 | 0 | 0 | 0 | 80 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 5
19. | Coffee substitutes | 0 | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
20. | Carbonated soft drinks, regular | 72 | 114 | 0 | 0 | 0 | 110 | 296 | 495 | 5 | 7 | 0 | 0 | 0 | 7 | 20 | 33
21. | Carbonated soft drinks, low calorie | 4 | 23 | 0 | 0 | 0 | 0 | 0 | 118 | 0 | 2 | 0 | 0 | 0 | 0 | 0 | 8
22. | Non-carbonated soft drinks, regular | 75 | 124 | 0 | 0 | 0 | 111 | 333 | 518 | 5 | 8 | 0 | 0 | 0 | 8 | 22 | 36
23. | Non-carbonated soft drinks, low calorie | 5 | 39 | 0 | 0 | 0 | 0 | 0 | 177 | 0 | 2 | 0 | 0 | 0 | 0 | 0 | 11
24. | Beer | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
25. | Wine | 0 | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
26. | Spirits, liqueurs, and mixed drinks | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
27. | Baby fruit juice | 1 | 9 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0
28. | Baby food (excluding baby fruit juice) | 4 | 38 | 0 | 0 | 0 | 0 | 0 | 100 | 0 | 3 | 0 | 0 | 0 | 0 | 0 | 8
| All Sources | 1559 | 507 | 838 | 1210 | 1497 | 1843 | 2507 | 3013 | 100

§ Does not include breast-fed children.

◆ Individual values may not add to totals due to rounding.

¶ Actual number of observations = 5605; weighted number of observations = 6354.1.

0 Less than 0.5 g/day or less than 0.5 percent.

Set H. Table 51 Dietary Sources of Total Water of Males and Females (Ages 11-19 Years) (All Regions, All Seasons) ^§◆^

| | g/day | | | | | | | | % of Total g/day
Sources of Total Water | | Mean^¶^ | Standard Deviation | 5 | 25 | 50 | 75 | 95 | 99 | Mean | Standard Deviation | 5 | 25 | 50 | 75 | 95 | 99
1. | Drinking water | 664 | 483 | 0 | 320 | 560 | 880 | 1600 | 2160 | 31 | 17 | 0 | 20 | 31 | 42 | 60 | 73
2. | Baby formula | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
3. | Milk | 339 | 278 | 0 | 143 | 286 | 481 | 856 | 1216 | 17 | 13 | 0 | 7 | 16 | 25 | 41 | 52
4. | Milk drinks | 38 | 87 | 0 | 0 | 0 | 49 | 205 | 383 | 2 | 5 | 0 | 0 | 0 | 2 | 11 | 21
5. | Other dairy products | 26 | 39 | 0 | 0 | 9 | 36 | 102 | 182 | 1 | 2 | 0 | 0 | 1 | 2 | 5 | 9
6. | Meat, poultry, fish and mixtures thereof | 122 | 75 | 32 | 71 | 107 | 155 | 264 | 386 | 6 | 4 | 2 | 4 | 6 | 8 | 14 | 20
7. | Eggs and egg dishes | 17 | 25 | 0 | 0 | 0 | 25 | 66 | 107 | 1 | 1 | 0 | 0 | 0 | 1 | 3 | 5
8. | Legumes, nuts and seeds | 17 | 38 | 0 | 0 | 0 | 14 | 88 | 197 | 1 | 2 | 0 | 0 | 0 | 1 | 5 | 9
9. | Grains and grain products | 122 | 101 | 17 | 49 | 95 | 167 | 317 | 459 | 6 | 5 | 1 | 3 | 5 | 9 | 16 | 23
10. | Citrus juices | 49 | 80 | 0 | 0 | 0 | 73 | 219 | 329 | 3 | 4 | 0 | 0 | 0 | 4 | 11 | 18
11. | Non-citrus fruit juices and tomato juice | 9 | 39 | 0 | 0 | 0 | 0 | 70 | 210 | 0 | 2 | 0 | 0 | 0 | 0 | 4 | 11
12. | Fruits | 57 | 79 | 0 | 0 | 30 | 86 | 217 | 326 | 3 | 4 | 0 | 0 | 1 | 5 | 11 | 17
13. | Potatoes | 47 | 53 | 0 | 9 | 31 | 68 | 145 | 235 | 2 | 3 | 0 | 0 | 2 | 4 | 7 | 12
14. | Vegetables and tomatoes | 94 | 85 | 0 | 33 | 74 | 133 | 256 | 392 | 5 | 4 | 0 | 2 | 4 | 7 | 13 | 19
15. | Fats, oils and dressings | 3 | 4 | 0 | 0 | 1 | 3 | 10 | 19 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 1
16. | Sugars and sweets | 11 | 27 | 0 | 0 | 1 | 7 | 67 | 133 | 1 | 1 | 0 | 0 | 0 | 0 | 3 | 7
17. | Tea | 87 | 183 | 0 | 0 | 0 | 96 | 463 | 832 | 4 | 9 | 0 | 0 | 0 | 6 | 23 | 39
18. | Coffee | 32 | 123 | 0 | 0 | 0 | 0 | 239 | 557 | 2 | 5 | 0 | 0 | 0 | 0 | 11 | 26
19. | Coffee substitutes | 0 | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
20. | Carbonated soft drinks, regular | 165 | 207 | 0 | 0 | 109 | 257 | 569 | 887 | 9 | 11 | 0 | 0 | 5 | 14 | 31 | 47
21. | Carbonated soft drinks, low calorie | 13 | 71 | 0 | 0 | 0 | 0 | 79 | 354 | 1 | 4 | 0 | 0 | 0 | 0 | 5 | 20
22. | Non-carbonated soft drinks, regular | 67 | 139 | 0 | 0 | 0 | 74 | 351 | 626 | 3 | 7 | 0 | 0 | 0 | 5 | 18 | 32
23. | Non-carbonated soft drinks, low calorie | 4 | 37 | 0 | 0 | 0 | 0 | 0 | 157 | 0 | 2 | 0 | 0 | 0 | 0 | 0 | 7
24. | Beer | 7 | 69 | 0 | 0 | 0 | 0 | 0 | 221 | 0 | 3 | 0 | 0 | 0 | 0 | 0 | 10
25. | Wine | 1 | 8 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0
26. | Spirits, liqueurs, and mixed drinks | 0 | 8 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
27. | Baby fruit juice | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
28. | Baby food (excluding baby fruit juice) | 0 | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| All Sources | 1989 | 719 | 1025 | 1489 | 1874 | 2369 | 3336 | 4251 | 100

§ Does not include pregnant women or lactating women.

◆ Individual values may not add to totals due to rounding.

¶ Actual number of observations = 5801; weighted number of observations = 6824.9.

0 Less than 0.5 g/day or less than 0.5 percent.

Set H. Table 52 Dietary Sources of Total Water of Males and Females (Ages 20–64 Years) (All Regions, All Seasons) ^§◆^

| | g/day | | | | | | | | % of Total g/day
Sources of Total Water | | Mean^¶^ | Standard Deviation | 5 | 25 | 50 | 75 | 95 | 99 | Mean | Standard Deviation | 5 | 25 | 50 | 75 | 95 | 99
1. | Drinking water | 674 | 555 | 0 | 320 | 560 | 960 | 1760 | 2560 | 28 | 17 | 0 | 16 | 28 | 40 | 59 | 71
2. | Baby formula | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
3. | Milk | 154 | 196 | 0 | 0 | 89 | 217 | 535 | 856 | 7 | 9 | 0 | 0 | 4 | 11 | 25 | 39
4. | Milk drinks | 11 | 45 | 0 | 0 | 0 | 0 | 80 | 215 | 1 | 2 | 0 | 0 | 0 | 0 | 4 | 11
5. | Other dairy products | 27 | 43 | 0 | 0 | 10 | 38 | 109 | 190 | 1 | 2 | 0 | 0 | 1 | 2 | 5 | 9
6. | Meat, poultry, fish and mixtures thereof | 133 | 84 | 33 | 76 | 116 | 171 | 293 | 408 | 6 | 4 | 2 | 4 | 5 | 8 | 14 | 21
7. | Eggs and egg dishes | 21 | 27 | 0 | 0 | 12 | 33 | 74 | 113 | 1 | 1 | 0 | 0 | 1 | 2 | 4 | 6
8. | Legumes, nuts and seeds | 15 | 36 | 0 | 0 | 0 | 2 | 88 | 175 | 1 | 2 | 0 | 0 | 0 | 0 | 4 | 8
9. | Grains and grain products | 100 | 94 | 10 | 35 | 73 | 136 | 286 | 435 | 5 | 4 | 0 | 2 | 3 | 6 | 13 | 20
10. | Citrus juices | 46 | 82 | 0 | 0 | 0 | 73 | 201 | 336 | 2 | 4 | 0 | 0 | 0 | 3 | 10 | 17
11. | Non-citrus fruit juices and tomato juice | 14 | 48 | 0 | 0 | 0 | 0 | 105 | 225 | 1 | 2 | 0 | 0 | 0 | 0 | 5 | 11
12. | Fruits | 61 | 92 | 0 | 0 | 24 | 89 | 242 | 403 | 3 | 4 | 0 | 0 | 1 | 4 | 11 | 18
13. | Potatoes | 45 | 53 | 0 | 2 | 31 | 63 | 147 | 228 | 2 | 2 | 0 | 0 | 1 | 3 | 7 | 11
14. | Vegetables and tomatoes | 132 | 103 | 7 | 60 | 110 | 181 | 330 | 461 | 6 | 5 | 0 | 3 | 5 | 8 | 15 | 22
15. | Fats, oils and dressings | 4 | 6 | 0 | 0 | 2 | 5 | 13 | 24 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 1
16. | Sugars and sweets | 7 | 22 | 0 | 0 | 0 | 3 | 40 | 104 | 0 | 1 | 0 | 0 | 0 | 0 | 2 | 5
17. | Tea | 152 | 259 | 0 | 0 | 0 | 234 | 634 | 1139 | 7 | 11 | 0 | 0 | 0 | 11 | 30 | 49
18. | Coffee | 395 | 447 | 0 | 0 | 298 | 557 | 1194 | 1990 | 17 | 17 | 0 | 0 | 14 | 27 | 49 | 67
19. | Coffee substitutes | 1 | 23 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0
20. | Carbonated soft drinks, regular | 117 | 201 | 0 | 0 | 0 | 165 | 495 | 881 | 6 | 10 | 0 | 0 | 0 | 8 | 25 | 45
21. | Carbonated soft drinks, low calorie | 30 | 115 | 0 | 0 | 0 | 0 | 236 | 590 | 1 | 5 | 0 | 0 | 0 | 0 | 11 | 28
22. | Non-carbonated soft drinks, regular | 30 | 96 | 0 | 0 | 0 | 0 | 218 | 441 | 1 | 4 | 0 | 0 | 0 | 0 | 9 | 23
23. | Non-carbonated soft drinks, low calorie | 2 | 24 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0
24. | Beer | 58 | 218 | 0 | 0 | 0 | 0 | 414 | 1004 | 2 | 7 | 0 | 0 | 0 | 0 | 16 | 36
25. | Wine | 7 | 38 | 0 | 0 | 0 | 0 | 49 | 181 | 0 | 2 | 0 | 0 | 0 | 0 | 2 | 9
26. | Spirits, liqueurs, and mixed drinks | 5 | 33 | 0 | 0 | 0 | 0 | 25 | 127 | 0 | 1 | 0 | 0 | 0 | 0 | 1 | 6
27. | Baby fruit juice | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
28. | Baby food (excluding baby fruit juice) | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| All Sources | 2243 | 839 | 1133 | 1665 | 2109 | 2663 | 3793 | 5081 | 100

§ Does not include pregnant women or lactating women.

◆ Individual values may not add to totals due to rounding.

¶ Actual number of observations = 11731; weighted number of observations = 21,744.9.

0 Less than 0.5 g/day or less than 0.5 percent.

Set H. Table 53 Dietary Sources of Total Water of Males and Females (Ages 65 Years and Over) (All Regions, All Seasons) ^§^

| | g/day | | | | | | | | % of Total g/day
Sources of Total Water | | Mean^◆^ | Standard Deviation | 5 | 25 | 50 | 75 | 95 | 99 | Mean | Standard Deviation | 5 | 25 | 50 | 75 | 95 | 99
1. | Drinking water | 776 | 554 | 0 | 400 | 720 | 1040 | 1920 | 2400 | 33 | 17 | 0 | 22 | 33 | 45 | 61 | 74
2. | Baby formula | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
3. | Milk | 165 | 174 | 0 | 27 | 116 | 245 | 499 | 734 | 8 | 8 | 0 | 1 | 6 | 11 | 23 | 36
4. | Milk drinks | 6 | 32 | 0 | 0 | 0 | 0 | 0 | 177 | 0 | 2 | 0 | 0 | 0 | 0 | 0 | 9
5. | Other dairy products | 32 | 46 | 0 | 0 | 13 | 43 | 123 | 209 | 1 | 2 | 0 | 0 | 1 | 2 | 5 | 9
6. | Meat, poultry, fish and mixtures thereof | 109 | 78 | 21 | 57 | 90 | 142 | 251 | 380 | 5 | 4 | 1 | 3 | 4 | 7 | 12 | 19
7. | Eggs and egg dishes | 21 | 24 | 0 | 0 | 12 | 33 | 66 | 98 | 1 | 1 | 0 | 0 | 1 | 2 | 3 | 5
8. | Legumes, nuts and seeds | 11 | 30 | 0 | 0 | 0 | 0 | 71 | 148 | 1 | 2 | 0 | 0 | 0 | 0 | 3 | 8
9. | Grains and grain products | 102 | 96 | 12 | 31 | 71 | 140 | 302 | 440 | 5 | 4 | 1 | 2 | 3 | 7 | 13 | 20
10. | Citrus juices | 50 | 77 | 0 | 0 | 0 | 101 | 217 | 292 | 2 | 4 | 0 | 0 | 0 | 4 | 10 | 15
11. | Non-citrus fruit juices and tomato juice | 16 | 50 | 0 | 0 | 0 | 0 | 108 | 217 | 1 | 2 | 0 | 0 | 0 | 0 | 5 | 11
12. | Fruits | 94 | 115 | 0 | 0 | 60 | 141 | 303 | 514 | 4 | 5 | 0 | 0 | 3 | 7 | 13 | 22
13. | Potatoes | 46 | 53 | 0 | 0 | 32 | 67 | 143 | 245 | 2 | 3 | 0 | 0 | 2 | 3 | 7 | 12
14. | Vegetables and tomatoes | 147 | 109 | 8 | 69 | 129 | 201 | 343 | 515 | 7 | 5 | 0 | 3 | 6 | 9 | 16 | 24
15. | Fats, oils and dressings | 3 | 4 | 0 | 1 | 2 | 4 | 11 | 20 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1
16. | Sugars and sweets | 11 | 30 | 0 | 0 | 0 | 5 | 68 | 146 | 1 | 1 | 0 | 0 | 0 | 0 | 3 | 7
17. | Tea | 137 | 217 | 0 | 0 | 0 | 231 | 552 | 925 | 6 | 10 | 0 | 0 | 0 | 10 | 27 | 42
18. | Coffee | 393 | 327 | 0 | 179 | 318 | 557 | 955 | 1433 | 18 | 14 | 0 | 9 | 16 | 26 | 44 | 60
19. | Coffee substitutes | 5 | 47 | 0 | 0 | 0 | 0 | 0 | 232 | 0 | 2 | 0 | 0 | 0 | 0 | 0 | 8
20. | Carbonated soft drinks, regular | 28 | 85 | 0 | 0 | 0 | 0 | 186 | 440 | 1 | 4 | 0 | 0 | 0 | 0 | 10 | 20
21. | Carbonated soft drinks, low calorie | 9 | 71 | 0 | 0 | 0 | 0 | 0 | 236 | 0 | 3 | 0 | 0 | 0 | 0 | 0 | 12
22. | Non-carbonated soft drinks, regular | 16 | 68 | 0 | 0 | 0 | 0 | 108 | 328 | 1 | 3 | 0 | 0 | 0 | 0 | 5 | 15
23. | Non-carbonated soft drinks, low calorie | 1 | 16 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0
24. | Beer | 18 | 110 | 0 | 0 | 0 | 0 | 0 | 607 | 1 | 4 | 0 | 0 | 0 | 0 | 0 | 23
25. | Wine | 3 | 19 | 0 | 0 | 0 | 0 | 0 | 99 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 4
26. | Spirits, liqueurs, and mixed drinks | 2 | 14 | 0 | 0 | 0 | 0 | 6 | 65 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 3
27. | Baby fruit juice | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
28. | Baby food (excluding baby fruit juice) | 0 | 8 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| All Sources | 2199 | 728 | 1196 | 1700 | 2109 | 2616 | 3482 | 4370 | 100

§ Individual values may not add to totals due to rounding.

◆ Actual number of observations = 2541; weighted number of observations = 4142.0.

0 Less than 0.5 g/day or less than 0.5 percent.

Set H. Table 54 Dietary Sources of Total Water of Pregnant Women (All Regions, All Seasons)^§^

| | g/day | | | | | | | % of Total g/day
Sources of Total Water | | Mean^◆^ | Standard Deviation | 5 | 25 | 50 | 75 | 95 | Mean | Standard Deviation | 5 | 25 | 50 | 75 | 95
1. | Drinking water | 695 | 525 | 0 | 320 | 640 | 960 | 1760 | 32 | 19 | 0 | 18 | 30 | 43 | 66
2. | Baby formula | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
3. | Milk | 282 | 230 | 0 | 98 | 233 | 406 | 722 | 15 | 12 | 0 | 5 | 12 | 22 | 40
4. | Milk drinks | 26 | 78 | 0 | 0 | 0 | 0 | 203 | 1 | 4 | 0 | 0 | 0 | 0 | 9
5. | Other dairy products | 24 | 34 | 0 | 0 | 9 | 34 | 93 | 1 | 2 | 0 | 0 | 0 | 2 | 6
6. | Meat, poultry, fish and mixtures thereof | 102 | 64 | 25 | 57 | 90 | 125 | 225 | 6 | 5 | 1 | 3 | 4 | 7 | 13
7. | Eggs and egg dishes | 19 | 26 | 0 | 0 | 0 | 33 | 76 | 1 | 1 | 0 | 0 | 0 | 2 | 4
8. | Legumes, nuts and seeds | 18 | 32 | 0 | 0 | 0 | 30 | 88 | 1 | 2 | 0 | 0 | 0 | 1 | 4
9. | Grains and grain products | 98 | 92 | 15 | 35 | 69 | 131 | 246 | 5 | 5 | 1 | 2 | 4 | 7 | 15
10. | Citrus juices | 56 | 107 | 0 | 0 | 0 | 82 | 219 | 3 | 5 | 0 | 0 | 0 | 5 | 12
11. | Non-citrus fruit juices and tomato juice | 14 | 42 | 0 | 0 | 0 | 0 | 114 | 1 | 2 | 0 | 0 | 0 | 0 | 6
12. | Fruits | 74 | 98 | 0 | 0 | 41 | 110 | 265 | 4 | 5 | 0 | 0 | 2 | 6 | 14
13. | Potatoes | 37 | 42 | 0 | 2 | 25 | 56 | 122 | 2 | 2 | 0 | 0 | 1 | 3 | 7
14. | Vegetables and tomatoes | 101 | 85 | 4 | 37 | 81 | 150 | 251 | 5 | 4 | 0 | 2 | 4 | 8 | 13
15. | Fats, oils and dressings | 3 | 4 | 0 | 0 | 1 | 3 | 10 | 0 | 0 | 0 | 0 | 0 | 0 | 0
16. | Sugars and sweets | 7 | 22 | 0 | 0 | 0 | 4 | 38 | 0 | 1 | 0 | 0 | 0 | 0 | 2
17. | Tea | 132 | 256 | 0 | 0 | 0 | 174 | 617 | 6 | 10 | 0 | 0 | 0 | 8 | 31
18. | Coffee | 197 | 379 | 0 | 0 | 0 | 239 | 955 | 8 | 13 | 0 | 0 | 0 | 13 | 41
19. | Coffee substitutes | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
20. | Carbonated soft drinks, regular | 122 | 163 | 0 | 0 | 73 | 220 | 440 | 6 | 8 | 0 | 0 | 3 | 11 | 24
21. | Carbonated soft drinks, low calorie | 8 | 46 | 0 | 0 | 0 | 0 | 0 | 0 | 2 | 0 | 0 | 0 | 0 | 0
22. | Non-carbonated soft drinks, regular | 47 | 91 | 0 | 0 | 0 | 54 | 240 | 2 | 4 | 0 | 0 | 0 | 3 | 13
23. | Non-carbonated soft drinks, low calorie | 1 | 14 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0
24. | Beer | 7 | 59 | 0 | 0 | 0 | 0 | 0 | 0 | 3 | 0 | 0 | 0 | 0 | 0
25. | Wine | 4 | 22 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0
26. | Spirits, liqueurs, and mixed drinks | 1 | 5 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0
27. | Baby fruit juice | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
28. | Baby food (excluding baby fruit juice) | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| All Sources | 2076 | 743 | 1085 | 1553 | 1928 | 2444 | 3475 | 100

§ Individual values may not add to totals due to rounding.

◆ Actual number of observations = 188; weighted number of observations = 327.5.

0 Less than 0.5 g/day or less than 0.5 percent.

Set H. Table 55 Dietary Sources of Total Water of Lactating Women (All Regions, All Seasons)^§^

| | g/day | | | | | | | % of Total g/day
Sources of Total Water | | Mean^◆^ | Standard Deviation | 5 | 25 | 50 | 75 | 95 | Mean | Standard Deviation | 5 | 25 | 50 | 75 | 95
1. | Drinking water | 677 | 492 | 0 | 240 | 560 | 1040 | 1600 | 29 | 18 | 0 | 13 | 29 | 44 | 55
2. | Baby formula | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
3. | Milk | 295 | 262 | 0 | 81 | 275 | 416 | 820 | 13 | 10 | 0 | 6 | 12 | 18 | 32
4. | Milk drinks | 11 | 43 | 0 | 0 | 0 | 0 | 79 | 1 | 2 | 0 | 0 | 0 | 0 | 3
5. | Other dairy products | 36 | 38 | 0 | 7 | 27 | 54 | 113 | 2 | 2 | 0 | 0 | 1 | 2 | 5
6. | Meat, poultry, fish and mixtures thereof | 106 | 61 | 19 | 66 | 97 | 138 | 211 | 5 | 3 | 1 | 3 | 5 | 7 | 11
7. | Eggs and egg dishes | 26 | 28 | 0 | 0 | 25 | 39 | 80 | 1 | 1 | 0 | 0 | 1 | 2 | 4
8. | Legumes, nuts and seeds | 15 | 32 | 0 | 0 | 0 | 15 | 72 | 1 | 1 | 0 | 0 | 0 | 1 | 4
9. | Grains and grain products | 119 | 125 | 13 | 32 | 82 | 161 | 387 | 5 | 5 | 1 | 2 | 3 | 8 | 15
10. | Citrus juices | 51 | 117 | 0 | 0 | 0 | 73 | 183 | 2 | 5 | 0 | 0 | 0 | 4 | 8
11. | Non-citrus fruit juices and tomato juice | 13 | 36 | 0 | 0 | 0 | 0 | 106 | 1 | 2 | 0 | 0 | 0 | 0 | 7
12. | Fruits | 73 | 98 | 0 | 0 | 46 | 99 | 278 | 3 | 4 | 0 | 0 | 2 | 5 | 12
13. | Potatoes | 41 | 52 | 0 | 1 | 28 | 63 | 121 | 2 | 2 | 0 | 0 | 1 | 3 | 7
14. | Vegetables and tomatoes | 131 | 116 | 17 | 52 | 100 | 170 | 296 | 6 | 4 | 1 | 3 | 5 | 8 | 12
15. | Fats, oils and dressings | 4 | 4 | 0 | 1 | 3 | 6 | 11 | 0 | 0 | 0 | 0 | 0 | 0 | 1
16. | Sugars and sweets | 6 | 16 | 0 | 0 | 1 | 3 | 50 | 0 | 1 | 0 | 0 | 0 | 0 | 2
17. | Tea | 253 | 513 | 0 | 0 | 77 | 308 | 848 | 11 | 17 | 0 | 0 | 4 | 15 | 45
18. | Coffee | 200 | 277 | 0 | 0 | 80 | 318 | 955 | 10 | 12 | 0 | 0 | 3 | 16 | 36
19. | Coffee substitutes | 5 | 34 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0
20. | Carbonated soft drinks, regular | 88 | 154 | 0 | 0 | 0 | 109 | 440 | 5 | 8 | 0 | 0 | 0 | 6 | 24
21. | Carbonated soft drinks, low calorie | 29 | 86 | 0 | 0 | 0 | 0 | 314 | 1 | 4 | 0 | 0 | 0 | 0 | 14
22. | Non-carbonated soft drinks, regular | 35 | 79 | 0 | 0 | 0 | 0 | 222 | 2 | 4 | 0 | 0 | 0 | 0 | 12
23. | Non-carbonated soft drinks, low calorie | 3 | 17 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0
24. | Beer | 17 | 63 | 0 | 0 | 0 | 0 | 147 | 1 | 3 | 0 | 0 | 0 | 0 | 8
25. | Wine | 6 | 24 | 0 | 0 | 0 | 0 | 49 | 0 | 1 | 0 | 0 | 0 | 0 | 2
26. | Spirits, liqueurs, and mixed drinks | 0 | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
27. | Baby fruit juice | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
28. | Baby food (excluding baby fruit juice) | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| All Sources | 2242 | 658 | 1185 | 1833 | 2164 | 2658 | 3353 | 100

§ Individual values may not add to totals due to rounding.

◆ Actual number of observations = 77; weighted number of observations = 151.2.

0 Less than 0.5 g/day or less than 0.5 percent.

Set H. Table 56 Dietary Sources of Total Water of Male and Female Breast-fed Children (All Ages) (All Regions, All Seasons) ^§♦^

Sources of Total Water | | g/day | | | | | | | % of Total g/day
Sources of Total Water | | Mean ^¶^ | Standard Deviation | 5 | 25 | 50 | 75 | 95 | Mean | Standard Deviation | 5 | 25 | 50 | 75 | 95
1. | Drinking water | 110 | 140 | 0 | 0 | 0 | 240 | 320 | 28 | 33 | 0 | 0 | 21 | 43 | 100
2. | Baby formula | 67 | 171 | 0 | 0 | 0 | 0 | 518 | 14 | 29 | 0 | 0 | 0 | 0 | 85
3. | Milk | 61 | 103 | 0 | 0 | 0 | 90 | 281 | 14 | 21 | 0 | 0 | 0 | 23 | 62
4. | Milk drinks | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
5. | Other dairy products | 4 | 12 | 0 | 0 | 0 | 0 | 23 | 1 | 5 | 0 | 0 | 0 | 0 | 6
6. | Meat, poultry, fish and mixtures thereof | 4 | 13 | 0 | 0 | 0 | 0 | 33 | 1 | 3 | 0 | 0 | 0 | 0 | 6
7. | Eggs and egg dishes | 3 | 9 | 0 | 0 | 0 | 0 | 24 | 0 | 1 | 0 | 0 | 0 | 0 | 4
8. | Legumes, nuts and seeds | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
9. | Grains and grain products | 15 | 39 | 0 | 0 | 0 | 1 | 104 | 3 | 8 | 0 | 0 | 0 | 1 | 16
10. | Citrus juices | 9 | 39 | 0 | 0 | 0 | 0 | 73 | 2 | 6 | 0 | 0 | 0 | 0 | 15
11. | Non-citrus fruit juices and tomato juice | 8 | 26 | 0 | 0 | 0 | 0 | 54 | 2 | 7 | 0 | 0 | 0 | 0 | 17
12. | Fruits | 18 | 36 | 0 | 0 | 0 | 12 | 107 | 7 | 16 | 0 | 0 | 0 | 5 | 43
13. | Potatoes | 1 | 4 | 0 | 0 | 0 | 0 | 4 | 0 | 1 | 0 | 0 | 0 | 0 | 4
14. | Vegetables and tomatoes | 7 | 20 | 0 | 0 | 0 | 0 | 60 | 2 | 6 | 0 | 0 | 0 | 2 | 11
15. | Fats, oils and dressings | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
16. | Sugars and sweets | 1 | 3 | 0 | 0 | 0 | 0 | 4 | 0 | 1 | 0 | 0 | 0 | 0 | 2
17. | Tea | 3 | 15 | 0 | 0 | 0 | 0 | 0 | 0 | 2 | 0 | 0 | 0 | 0 | 0
18. | Coffee | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
19. | Coffee substitutes | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
20. | Carbonated soft drinks, regular | 1 | 8 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0
21. | Carbonated soft drinks, low calorie | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
22. | Non-carbonated soft drinks, regular | 4 | 18 | 0 | 0 | 0 | 0 | 9 | 1 | 2 | 0 | 0 | 0 | 0 | 6
23. | Non-carbonated soft drinks, low calorie | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
24. | Beer | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
25. | Wine | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
26. | Spirits, liqueurs, and mixed drinks | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
27. | Baby fruit juice | 9 | 29 | 0 | 0 | 0 | 0 | 73 | 4 | 14 | 0 | 0 | 0 | 0 | 20
28. | Baby food (excluding baby fruit juice) | 76 | 118 | 0 | 0 | 1 | 112 | 331 | 20 | 26 | 0 | 0 | 10 | 30 | 77
| All Sources | 402 | 352 | 0 | 69 | 315 | 633 | 1023 | 100

§ Contribution of breast milk not included.

♦ Individual values may not add to totals due to rounding.

¶ Actual number of observations = 100; weighted number of observations = 121.0.

0 Less than 0.5 g/day or less than 0.5 percent.

### I GENERAL DIETARY SOURCES OF TAPWATER

Set I. Table 57 General Dietary Sources of Tapwater by Broad Age Category (Both Sexes, All Regions, All Seasons) ^§♦¶^

Age (yr) | Number of Observations | | Source | g/day | | | | | | | | % of Tap g/day
Age (yr) | Actual Count | Weighted Count | Source | Mean | Standard Deviation | 5 | 25 | 50 | 75 | 95 | 99 | Mean | Standard Deviation | 5 | 25 | 50 | 75 | 95 | 99
< 1 | 403 | 444.3 | Food ^+^ | 25 | 55 | 0 | 0 | 0 | 18 | 156 | 257 | 11 | 24 | 0 | 0 | 0 | 10 | 70 | 100
| | | Drinking Hater | 197 | 186 | 0 | 0 | 240 | 240 | 480 | 880 | 69 | 37 | 0 | 39 | 87 | 100 | 100 | 100
| | | Other Beverages | 81 | 167 | 0 | 0 | 0 | 55 | 496 | 686 | 20 | 33 | 0 | 0 | 0 | 22 | 100 | 100
| | | All Sources | 302 | 258 | 0 | 113 | 240 | 424 | 775 | 1102 | 100
1–10 | 5605 | 6354.1 | Food ^+^ | 87 | 81 | 0 | 29 | 67 | 122 | 244 | 365 | 15 | 16 | 0 | 5 | 10 | 19 | 44 | 100
| | | Drinking Water | 505 | 354 | 0 | 240 | 480 | 720 | 1200 | 1600 | 65 | 25 | 0 | 52 | 70 | 84 | 96 | 100
| | | Other Beverages | 144 | 167 | 0 | 0 | 92 | 215 | 463 | 721 | 20 | 21 | 0 | 0 | 15 | 32 | 63 | 93
| | | All Sources | 736 | 410 | 192 | 442 | 665 | 960 | 1516 | 1954 | 100
11–19 | 5801 | 6824.9 | Food ^+^ | 95 | 95 | 0 | 28 | 70 | 137 | 272 | 399 | 13 | 15 | 0 | 3 | 8 | 17 | 38 | 100
| | | Drinking Water | 664 | 483 | 0 | 320 | 560 | 880 | 1600 | 2160 | 65 | 25 | 0 | 52 | 70 | 85 | 98 | 100
| | | Other Beverages | 206 | 251 | 0 | 0 | 138 | 299 | 671 | 1132 | 22 | 23 | 0 | 0 | 16 | 34 | 68 | 96
| | | All Sources | 965 | 562 | 240 | 574 | 867 | 1246 | 2026 | 2748 | 100
20–64 | 11731 | 21744.9 | Food ^+^ | 87 | 93 | 0 | 21 | 64 | 124 | 268 | 424 | 8 | 10 | 0 | 2 | 5 | 11 | 25 | 49
| | | Drinking Water | 674 | 555 | 0 | 320 | 560 | 960 | 1760 | 2560 | 47 | 26 | 0 | 29 | 48 | 67 | 91 | 100
| | | Other Beverages | 604 | 482 | 0 | 259 | 524 | 841 | 1448 | 2241 | 45 | 26 | 0 | 25 | 44 | 63 | 91 | 100
| | | All Sources | 1366 | 728 | 416 | 870 | 1252 | 1737 | 2707 | 3780 | 100
65+ | 2541 | 4142.0 | Food ^+^ | 101 | 105 | 0 | 22 | 72 | 146 | 301 | 466 | 8 | 9 | 0 | 2 | 5 | 11 | 23 | 38
| | | Drinking Water | 776 | 554 | 0 | 400 | 720 | 1040 | 1920 | 2400 | 50 | 23 | 0 | 36 | 52 | 66 | 87 | 99
| | | Other Beverages | 583 | 358 | 47 | 338 | 554 | 756 | 1228 | 1691 | 42 | 23 | 3 | 27 | 40 | 57 | 85 | 100
| | | All Sources | 1459 | 643 | 598 | 1019 | 1367 | 1806 | 2636 | 3338 | 100
All | 26081 | 39510.2 | Food ^+^ | 90 | 93 | 0 | 23 | 66 | 128 | 268 | 417 | 10 | 13 | 0 | 2 | 6 | 13 | 31 | 64
| | | Drinking Water | 651 | 520 | 0 | 240 | 560 | 880 | 1600 | 2400 | 54 | 27 | 0 | 36 | 56 | 75 | 95 | 100
| | | Other Beverages | 453 | 446 | 0 | 110 | 350 | 667 | 1270 | 1990 | 36 | 27 | 0 | 14 | 34 | 55 | 87 | 100
| | | All Sources | 1193 | 702 | 286 | 690 | 1081 | 1561 | 2477 | 3415 | 100

§ Does not include pregnant women, lactating women, or breast-fed children.

♦ Individual values may not add to totals due to rounding.

¶ Please see Discussion (Special Problem: Infants) (page 34) regarding limitations of Tapwater estimates for infants <1 year.

+ Food category includes soups.

0 Less than 0.5 g/day or less than 0.5 percent.

Set I. Table 58 General Dietary Sources of Tapwater of Pregnant Women, Lactating Women, and Breast-fed Children (All Regions, All Seasons) ^§♦^

| Number of Observations | | Source | g/day | | | | | | | % of Tap g/day
| Actual Count | Weighted Count | Source | Mean | Standard Deviation | 5 | 25 | 50 | 75 | 95 | Mean | Standard Deviation | 5 | 25 | 50 | 75 | 95
Pregnant women | 188 | 327.5 | Food ^¶^ | 82 | 88 | 0 | 21 | 61 | 108 | 244 | 10 | 17 | 0 | 2 | 6 | 11 | 43
| | | Drinking Water | 695 | 525 | 0 | 320 | 640 | 960 | 1760 | 56 | 28 | 0 | 36 | 60 | 80 | 96
| | | Other Beverages | 411 | 446 | 0 | 80 | 266 | 621 | 1353 | 33 | 27 | 0 | 12 | 29 | 52 | 82
| | | All Sources | 1189 | 699 | 274 | 713 | 1063 | 1501 | 2424
Lactating women | 77 | 151.2 | Food ^¶^ | 99 | 102 | 0 | 39 | 75 | 129 | 297 | 10 | 15 | 0 | 3 | 6 | 10 | 28
| | | Drinking Water | 677 | 492 | 0 | 240 | 560 | 1040 | 1600 | 49 | 29 | 0 | 24 | 52 | 71 | 90
| | | Other Beverages | 534 | 539 | 0 | 225 | 477 | 656 | 1274 | 41 | 28 | 0 | 19 | 37 | 63 | 90
| | | All Sources | 1310 | 591 | 430 | 855 | 1330 | 1693 | 2191
Breast-fed children | 100 | 121.0 | Food ^¶^ | 13 | 34 | 0 | 0 | 0 | 0 | 83 | 12 | 23 | 0 | 0 | 0 | 17 | 47
| | | Drinking Water | 110 | 140 | 0 | 0 | 0 | 240 | 320 | 68 | 40 | 0 | 46 | 90 | 100 | 100
| | | Other Beverages | 29 | 76 | 0 | 0 | 0 | 0 | 230 | 20 | 34 | 0 | 0 | 0 | 19 | 100
| | | All Sources | 153 | 175 | 0 | 0 | 89 | 249 | 468

§ Individual values may not add to totals due to rounding.

♦ Please see Discussion (Special Problem: Infants) (page 34) regarding limitations of Tapwater estimates for infants <1 year.

¶ Food category includes soups.

0 Less than 0.5 g/day or less than 0.5 percent.

### J DIETARY SOURCES OF TAPWATER

Set J. Table 59 Dietary Sources of Tapwater of Males and Females (Ages Under 1 Year) (All Regions, All Seasons) ^§♦¶^

Sources of Tapwater | | g/day | | | | | | | | % of Total g/day
Sources of Tapwater | | Mean ^+^ | Standard Deviation | 5 | 25 | 50 | 75 | 95 | 99 | Mean | Standard Deviation | 5 | 25 | 50 | 75 | 95 | 99
1. | Drinking water | 197 | 186 | 0 | 0 | 240 | 240 | 480 | 880 | 69 | 37 | 0 | 39 | 87 | 100 | 100 | 100
2. | Baby formula | 54 | 148 | 0 | 0 | 0 | 0 | 432 | 584 | 12 | 28 | 0 | 0 | 0 | 0 | 100 | 100
3. | Milk | 9 | 69 | 0 | 0 | 0 | 0 | 0 | 428 | 2 | 10 | 0 | 0 | 0 | 0 | 0 | 67
4. | Milk drinks | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
5. | Other dairy products | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
6. | Meat, poultry, fish and mixtures thereof | 1 | 8 | 0 | 0 | 0 | 0 | 9 | 31 | 1 | 7 | 0 | 0 | 0 | 0 | 4 | 27
7. | Eggs and egg dishes | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
8. | Legumes, nuts and seeds | 1 | 5 | 0 | 0 | 0 | 0 | 0 | 22 | 0 | 5 | 0 | 0 | 0 | 0 | 0 | 5
9. | Grains and grain products | 17 | 45 | 0 | 0 | 0 | 0 | 126 | 218 | 7 | 18 | 0 | 0 | 0 | 3 | 44 | 100
10. | Citrus juices | 7 | 25 | 0 | 0 | 0 | 0 | 54 | 123 | 3 | 13 | 0 | 0 | 0 | 0 | 16 | 100
11. | Non-citrus fruit juices and tomato juice | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
12. | Fruits | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
13. | Potatoes | 1 | 11 | 0 | 0 | 0 | 0 | 0 | 28 | 0 | 3 | 0 | 0 | 0 | 0 | 0 | 11
14. | Vegetables and tomatoes | 2 | 9 | 0 | 0 | 0 | 0 | 9 | 56 | 1 | 7 | 0 | 0 | 0 | 0 | 5 | 19
15. | Fats, oils and dressings | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
16. | Sugars and sweets | 2 | 14 | 0 | 0 | 0 | 0 | 0 | 67 | 1 | 9 | 0 | 0 | 0 | 0 | 2 | 17
17. | Tea | 7 | 43 | 0 | 0 | 0 | 0 | 10 | 317 | 2 | 10 | 0 | 0 | 0 | 0 | 5 | 71
18. | Coffee | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
19. | Coffee substitutes | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
20. | Carbonated soft drinks, regular | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
21. | Carbonated soft drinks, low calorie | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
22. | Non-carbonated soft drinks, regular | 4 | 22 | 0 | 0 | 0 | 0 | 18 | 148 | 1 | 8 | 0 | 0 | 0 | 0 | 7 | 40
23. | Non-carbonated soft drinks, low calorie | 0 | 4 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0
24. | Beer | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
25. | Wine | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
26. | Spirits, liqueurs, and mixed drinks | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
27. | Baby fruit juice | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
28. | Baby food (excluding baby fruit juice) | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| All Sources | 302 | 258 | 0 | 113 | 240 | 424 | 775 | 1102 | 100

§ Does not include breast-fed children.

♦ Individual values may not add to totals due to rounding.

¶ Please see Discussion (Special Problem: Infants) (page 34) regarding limitations of Tapwater estimates for infants <1 year.

+ Actual number of observations = 403; weighted number of observations = 444.3.

0 Less than 0.5 g/day or less than 0.5 percent.

Set J. Table 60 Dietary Sources of Tapwater of Males and Females (Ages 1–10 Years) (All Regions, All Seasons) ^§♦^

Sources of Tapwater | | g/day | | | | | | | | % of Total g/day
Sources of Tapwater | | Mean ^¶^ | Standard Deviation | 5 | 25 | 50 | 75 | 95 | 99 | Mean | Standard Deviation | 5 | 25 | 50 | 75 | 95 | 99
1. | Drinking water | 505 | 354 | 0 | 240 | 480 | 720 | 1200 | 1600 | 65 | 25 | 0 | 52 | 70 | 84 | 96 | 100
2. | Baby formula | 0 | 10 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0
3. | Milk | 5 | 40 | 0 | 0 | 0 | 0 | 0 | 167 | 1 | 4 | 0 | 0 | 0 | 0 | 0 | 20
4. | Milk drinks | 2 | 17 | 0 | 0 | 0 | 0 | 0 | 73 | 0 | 3 | 0 | 0 | 0 | 0 | 0 | 13
5. | Other dairy products | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
6. | Meat, poultry, fish and mixtures thereof | 12 | 24 | 0 | 0 | 0 | 16 | 63 | 110 | 2 | 5 | 0 | 0 | 0 | 2 | 10 | 21
7. | Eggs and egg dishes | 0 | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0
8. | Legumes, nuts and seeds | 7 | 18 | 0 | 0 | 0 | 2 | 41 | 88 | 1 | 3 | 0 | 0 | 0 | 0 | 6 | 15
9. | Grains and grain products | 53 | 65 | 0 | 5 | 33 | 76 | 181 | 297 | 9 | 14 | 0 | 1 | 5 | 12 | 33 | 71
10. | Citrus juices | 32 | 56 | 0 | 0 | 0 | 54 | 138 | 230 | 6 | 12 | 0 | 0 | 0 | 8 | 26 | 57
11. | Non-citrus fruit juices and tomato juice | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
12. | Fruits | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
13. | Potatoes | 1 | 8 | 0 | 0 | 0 | 0 | 0 | 42 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 7
14. | Vegetables and tomatoes | 7 | 19 | 0 | 0 | 0 | 0 | 41 | 80 | 1 | 4 | 0 | 0 | 0 | 0 | 8 | 18
15. | Fats, oils and dressings | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
16. | Sugars and sweets | 6 | 20 | 0 | 0 | 0 | 0 | 49 | 100 | 1 | 4 | 0 | 0 | 0 | 0 | 7 | 16
17. | Tea | 42 | 101 | 0 | 0 | 0 | 0 | 238 | 429 | 6 | 13 | 0 | 0 | 0 | 0 | 34 | 60
18. | Coffee | 2 | 18 | 0 | 0 | 0 | 0 | 0 | 80 | 0 | 3 | 0 | 0 | 0 | 0 | 0 | 10
19. | Coffee substitutes | 0 | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
20. | Carbonated soft drinks, regular | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
21. | Carbonated soft drinks, low calorie | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
22. | Non-carbonated soft drinks, regular | 56 | 114 | 0 | 0 | 0 | 74 | 296 | 499 | 7 | 14 | 0 | 0 | 0 | 10 | 39 | 65
23. | Non-carbonated soft drinks, low calorie | 4 | 36 | 0 | 0 | 0 | 0 | 0 | 157 | 0 | 4 | 0 | 0 | 0 | 0 | 0 | 18
24. | Beer | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
25. | Vine | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
26. | Spirits, liqueurs, and mixed drinks | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
27. | Baby fruit juice | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
28. | Baby food (excluding baby fruit juice) | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| All Sources | 736 | 410 | 192 | 442 | 665 | 960 | 1516 | 1954 | 100

§ Does not include breast-fed children.

♦ Individual values may not add to totals due to rounding.

¶ Actual number of observations = 5605; weighted number of observations = 6354.1.

0 Less than 0.5 g/day or less than 0.5 percent.

Set J. Table 61 Dietary Sources of Tapwater of Males and Females (Ages 11–19 Years) (All Regions, All Seasons) ^§♦^

Sources of Tapwater | | g/day | | | | | | | | % of Total g/day
Sources of Tapwater | | Mean ^¶^ | Standard Deviation | 5 | 25 | 50 | 75 | 95 | 99 | Mean | Standard Deviation | 5 | 25 | 50 | 75 | 95 | 99
1. | Drinking water | 664 | 483 | 0 | 320 | 560 | 880 | 1600 | 2160 | 65 | 25 | 0 | 52 | 70 | 85 | 98 | 100
2. | Baby formula | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
3. | Milk | 3 | 30 | 0 | 0 | 0 | 0 | 0 | 74 | 0 | 3 | 0 | 0 | 0 | 0 | 0 | 6
4. | Milk drinks | 3 | 19 | 0 | 0 | 0 | 0 | 0 | 102 | 0 | 3 | 0 | 0 | 0 | 0 | 0 | 16
5. | Other dairy products | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
6. | Meat, poultry, fish and mixtures thereof | 18 | 35 | 0 | 0 | 0 | 26 | 81 | 159 | 3 | 7 | 0 | 0 | 0 | 3 | 12 | 28
7. | Eggs and egg dishes | 0 | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
8. | Legumes, nuts and seeds | 10 | 27 | 0 | 0 | 0 | 0 | 60 | 131 | 1 | 5 | 0 | 0 | 0 | 0 | 7 | 17
9. | Grains and grain products | 52 | 71 | 0 | 0 | 30 | 73 | 185 | 315 | 7 | 11 | 0 | 0 | 3 | 9 | 26 | 49
10. | Citrus juices | 32 | 60 | 0 | 0 | 0 | 46 | 155 | 245 | 4 | 10 | 0 | 0 | 0 | 5 | 21 | 44
11. | Non-citrus fruit juices and tomato juice | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
12. | Fruits | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
13. | Potatoes | 2 | 11 | 0 | 0 | 0 | 0 | 0 | 56 | 0 | 3 | 0 | 0 | 0 | 0 | 0 | 8
14. | Vegetables and tomatoes | 6 | 22 | 0 | 0 | 0 | 0 | 38 | 112 | 1 | 3 | 0 | 0 | 0 | 0 | 6 | 16
15. | Fats, oils and dressings | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
16. | Sugars and sweets | 7 | 23 | 0 | 0 | 0 | 0 | 53 | 115 | 1 | 4 | 0 | 0 | 0 | 0 | 6 | 15
17. | Tea | 86 | 183 | 0 | 0 | 0 | 96 | 463 | 832 | 9 | 17 | 0 | 0 | 0 | 11 | 45 | 75
18. | Coffee | 32 | 123 | 0 | 0 | 0 | 0 | 239 | 557 | 3 | 10 | 0 | 0 | 0 | 0 | 23 | 54
19. | Coffee substitutes | 0 | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
20. | Carbonated soft drinks, regular | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
21. | Carbonated soft drinks, low calorie | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
22. | Non-carbonated soft drinks, regular | 48 | 120 | 0 | 0 | 0 | 0 | 291 | 555 | 5 | 12 | 0 | 0 | 0 | 0 | 31 | 56
23. | Non-carbonated soft drinks, low calorie | 3 | 34 | 0 | 0 | 0 | 0 | 0 | 98 | 0 | 3 | 0 | 0 | 0 | 0 | 0 | 10
24. | Beer | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
25. | Wine | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
26. | Spirits, liqueurs, and mixed drinks | 0 | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
27. | Baby fruit juice | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
28. | Baby food (excluding baby fruit juice) | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| All Sources | 965 | 562 | 240 | 574 | 867 | 1246 | 1701 | 2748 | 100

§ Does not include pregnant women or lactating women.

♦ Individual values may not add to totals due to rounding.

¶ Actual number of observations = 5801; weighted number of observations = 6824.9.

0 Less than 0.5 g/day or less than 0.5 percent.

Set J. Table 62 Dietary Sources of Tapwater of Males and Females (Ages 20–64 Years) (All Regions, All Seasons)^§♦^

Sources of Tapwater | | g/day | | | | | | | | % of Total g/day
Sources of Tapwater | | Mean^¶^ | Standard Deviation | 5 | 25 | 50 | 75 | 95 | 99 | Mean | Standard Deviation | 5 | 25 | 50 | 75 | 95 | 99
1. | Drinking water | 674 | 555 | 0 | 320 | 560 | 960 | 1760 | 2560 | 47 | 26 | 0 | 29 | 48 | 67 | 91 | 100
2. | Baby formula | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
3. | Milk | 3 | 33 | 0 | 0 | 0 | 0 | 0 | 83 | 0 | 2 | 0 | 0 | 0 | 0 | 0 | 7
4. | Milk drinks | 2 | 18 | 0 | 0 | 0 | 0 | 0 | 76 | 0 | 2 | 0 | 0 | 0 | 0 | 0 | 8
5. | Other dairy products | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
6. | Meat, poultry, fish and mixtures thereof | 18 | 36 | 0 | 0 | 0 | 23 | 88 | 170 | 2 | 5 | 0 | 0 | 0 | 2 | 8 | 18
7. | Eggs and egg dishes | 0 | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
8. | Legumes, nuts and seeds | 9 | 26 | 0 | 0 | 0 | 0 | 60 | 131 | 1 | 3 | 0 | 0 | 0 | 0 | 5 | 11
9. | Grains and grain products | 45 | 69 | 0 | 0 | 20 | 65 | 182 | 323 | 4 | 8 | 0 | 0 | 2 | 5 | 17 | 33
10. | Citrus juices | 27 | 56 | 0 | 0 | 0 | 31 | 138 | 238 | 3 | 6 | 0 | 0 | 0 | 3 | 13 | 26
11. | Non-citrus fruit juices and tomato juice | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
12. | Fruits | 0 | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
13. | Potatoes | 1 | 9 | 0 | 0 | 0 | 0 | 0 | 56 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 4
14. | Vegetables and tomatoes | 9 | 27 | 0 | 0 | 0 | 0 | 74 | 130 | 1 | 3 | 0 | 0 | 0 | 0 | 5 | 13
15. | Fats, oils and dressings | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
16. | Sugars and sweets | 4 | 19 | 0 | 0 | 0 | 0 | 33 | 97 | 0 | 2 | 0 | 0 | 0 | 0 | 2 | 8
17. | Tea | 152 | 259 | 0 | 0 | 0 | 234 | 634 | 1139 | 12 | 18 | 0 | 0 | 0 | 18 | 52 | 80
18. | Coffee | 395 | 447 | 0 | 0 | 298 | 557 | 1194 | 1990 | 28 | 26 | 0 | 0 | 24 | 46 | 78 | 95
19. | Coffee substitutes | 1 | 23 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 2 | 0 | 0 | 0 | 0 | 0 | 0
20. | Carbonated soft drinks, regular | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
21. | Carbonated soft drinks, low calorie | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
22. | Non-carbonated soft drinks, regular | 21 | 82 | 0 | 0 | 0 | 0 | 148 | 370 | 2 | 7 | 0 | 0 | 0 | 0 | 12 | 36
23. | Non-carbonated soft drinks, low calorie | 1 | 20 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0
24. | Beer | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
25. | Wine | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
26. | Spirits, liqueurs, and mixed drinks | 1 | 8 | 0 | 0 | 0 | 0 | 0 | 28 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 3
27. | Baby fruit juice | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
28. | Baby food (excluding baby fruit juice) | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| All Sources | 1366 | 728 | 416 | 870 | 1252 | 1737 | 2707 | 3780 | 100

§ Does not include pregnant women or lactating women.

♦ Individual values may not add to totals due to rounding.

¶ Actual number of observations = 11731; weighted number of observations = 21,744.9.

0 Less than 0.5 g/day or less than 0.5 percent.

Set J. Table 63 Dietary Sources of Tapwater of Males and Females (Ages 65 Years and Over) (All Regions, All Seasons) ^§^

Sources of Tapwater | | g/day | | | | | | | | % of Total g/day
Sources of Tapwater | | Mean ^♦^ | Standard Deviation | 5 | 25 | 50 | 75 | 95 | 99 | Mean | Standard Deviation | 5 | 25 | 50 | 75 | 95 | 99
1. | Drinking water | 776 | 554 | 0 | 400 | 720 | 1040 | 1920 | 2400 | 50 | 23 | 0 | 36 | 52 | 66 | 87 | 99
2. | Baby formula | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
3. | Milk | 6 | 42 | 0 | 0 | 0 | 0 | 0 | 222 | 0 | 3 | 0 | 0 | 0 | 0 | 0 | 15
4. | Milk drinks | 2 | 17 | 0 | 0 | 0 | 0 | 0 | 68 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 5
5. | Other dairy products | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
6. | Meat, poultry, fish and mixtures thereof | 17 | 37 | 0 | 0 | 0 | 18 | 93 | 163 | 1 | 3 | 0 | 0 | 0 | 1 | 7 | 14
7. | Eggs and egg dishes | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
8. | Legumes, nuts and seeds | 7 | 21 | 0 | 0 | 0 | 0 | 45 | 105 | 1 | 3 | 0 | 0 | 0 | 0 | 4 | 9
9. | Grains and grain products | 54 | 79 | 0 | 0 | 19 | 74 | 223 | 344 | 4 | 6 | 0 | 0 | 1 | 6 | 15 | 28
10. | Citrus juices | 28 | 55 | 0 | 0 | 0 | 38 | 138 | 215 | 2 | 5 | 0 | 0 | 0 | 3 | 11 | 19
11. | Non-citrus fruit juices and tomato juice | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
12. | Fruits | 1 | 6 | 0 | 0 | 0 | 0 | 3 | 32 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 2
13. | Potatoes | 2 | 12 | 0 | 0 | 0 | 0 | 0 | 56 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 4
14. | Vegetables and tomatoes | 12 | 32 | 0 | 0 | 0 | 0 | 74 | 141 | 1 | 3 | 0 | 0 | 0 | 0 | 6 | 13
15. | Fats, oils and dressings | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
16. | Sugars and sweets | 8 | 26 | 0 | 0 | 0 | 0 | 67 | 133 | 1 | 2 | 0 | 0 | 0 | 0 | 4 | 9
17. | Tea | 137 | 217 | 0 | 0 | 0 | 231 | 552 | 925 | 10 | 16 | 0 | 0 | 0 | 16 | 43 | 68
18. | Coffee | 393 | 327 | 0 | 179 | 318 | 557 | 955 | 1433 | 28 | 22 | 0 | 13 | 26 | 41 | 70 | 90
19. | Coffee substitutes | 5 | 47 | 0 | 0 | 0 | 0 | 0 | 232 | 0 | 4 | 0 | 0 | 0 | 0 | 0 | 13
20. | Carbonated soft drinks, regular | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
21. | Carbonated soft drinks, low calorie | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
22. | Non-carbonated soft drinks, regular | 10 | 57 | 0 | 0 | 0 | 0 | 73 | 282 | 1 | 4 | 0 | 0 | 0 | 0 | 4 | 17
23. | Non-carbonated soft drinks, low calorie | 1 | 15 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0
24. | Beer | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
25. | Wine | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
26. | Spirits, liqueurs, and mixed drinks | 0 | 3 | 0 | 0 | 0 | 0 | 0 | 12 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1
27. | Baby fruit juice | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
28. | Baby food (excluding baby fruit juice) | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| All Sources | 1459 | 643 | 598 | 1019 | 1367 | 1806 | 2636 | 3338 | 100

§ Individual values may not add to totals due to rounding.

♦ Actual number of observations = 2541; weighted number of observations = 4142.0.

0 Less than 0.5 g/day or less than 0.5 percent.

Set J. Table 64 Dietary Sources of Tapwater of Pregnant Women (All Regions, All Seasons) ^§^

Sources of Tapwater | | g/day | | | | | | | % of Total g/day
Sources of Tapwater | | Mean ^♦^ | Standard Deviation | 5 | 25 | 50 | 75 | 95 | Mean | Standard Deviation | 5 | 25 | 50 | 75 | 95
1. | Drinking water | 695 | 525 | 0 | 320 | 640 | 960 | 1760 | 56 | 28 | 0 | 36 | 60 | 80 | 96
2. | Baby formula | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
3. | Milk | 13 | 83 | 0 | 0 | 0 | 0 | 0 | 1 | 5 | 0 | 0 | 0 | 0 | 0
4. | Milk drinks | 3 | 22 | 0 | 0 | 0 | 0 | 0 | 0 | 3 | 0 | 0 | 0 | 0 | 0
5. | Other dairy products | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
6. | Meat, poultry, fish and mixtures thereof | 12 | 25 | 0 | 0 | 0 | 10 | 65 | 2 | 4 | 0 | 0 | 0 | 1 | 9
7. | Eggs and egg dishes | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
8. | Legumes, nuts and seeds | 11 | 24 | 0 | 0 | 0 | 15 | 54 | 1 | 3 | 0 | 0 | 0 | 1 | 6
9. | Grains and grain products | 46 | 71 | 0 | 0 | 21 | 69 | 170 | 6 | 13 | 0 | 0 | 2 | 6 | 21
10. | Citrus juices | 34 | 80 | 0 | 0 | 0 | 46 | 161 | 3 | 9 | 0 | 0 | 0 | 3 | 16
11. | Non-citrus fruit juices and tomato juice | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
12. | Fruits | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
13. | Potatoes | 1 | 8 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
14. | Vegetables and tomatoes | 8 | 24 | 0 | 0 | 0 | 0 | 56 | 1 | 9 | 0 | 0 | 0 | 0 | 5
15. | Fats, oils and dressings | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
16. | Sugars and sweets | 4 | 21 | 0 | 0 | 0 | 0 | 24 | 0 | 2 | 0 | 0 | 0 | 0 | 2
17. | Tea | 132 | 256 | 0 | 0 | 0 | 174 | 617 | 10 | 18 | 0 | 0 | 0 | 15 | 51
18. | Coffee | 197 | 379 | 0 | 0 | 0 | 239 | 955 | 15 | 23 | 0 | 0 | 0 | 24 | 66
19. | Coffee substitutes | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
20. | Carbonated soft drinks, regular | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
21. | Carbonated soft drinks, low calorie | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
22. | Non-carbonated soft drinks, regular | 30 | 71 | 0 | 0 | 0 | 0 | 203 | 3 | 8 | 0 | 0 | 0 | 0 | 19
23. | Non-carbonated soft drinks, low calorie | 1 | 12 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0
24. | Beer | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
25. | Wine | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
26. | Spirits, liqueurs, and mixed drinks | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
27. | Baby fruit juice | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
28. | Baby food (excluding baby fruit juice) | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| All Sources | 1189 | 699 | 274 | 713 | 1063 | 1501 | 2424 | 100

§ Individual values may not add to totals due to rounding.

♦ Actual number of observations = 188; weighted number of observations = 327.5.

0 Less than 0.5 g/day or less than 0.5 percent.

Set J. Table 65 Dietary Sources of Tapwater of Lactating Women (All Regions, All Seasons) ^§^

Sources of Tapwater | | g/day | | | | | | | % of Total g/day
Sources of Tapwater | | Mean ^♦^ | Standard Deviation | 5 | 25 | 50 | 75 | 95 | Mean | Standard Deviation | 5 | 25 | 50 | 75 | 95
1. | Drinking water | 677 | 492 | 0 | 240 | 560 | 1040 | 1600 | 49 | 29 | 0 | 24 | 52 | 71 | 90
2. | Baby formula | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
3. | Milk | 13 | 60 | 0 | 0 | 0 | 0 | 130 | 1 | 4 | 0 | 0 | 0 | 0 | 10
4. | Milk drinks | 1 | 10 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0
5. | Other dairy products | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
6. | Meat, poultry, fish and mixtures thereof | 15 | 27 | 0 | 0 | 0 | 15 | 70 | 1 | 3 | 0 | 0 | 0 | 1 | 9
7. | Eggs and egg dishes | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
8. | Legumes, nuts and seeds | 8 | 19 | 0 | 0 | 0 | 8 | 54 | 1 | 2 | 0 | 0 | 0 | 0 | 4
9. | Grains and grain products | 61 | 95 | 0 | 0 | 35 | 73 | 240 | 6 | 10 | 0 | 0 | 3 | 8 | 21
10. | Citrus juices | 39 | 98 | 0 | 0 | 0 | 61 | 153 | 3 | 7 | 0 | 0 | 0 | 4 | 15
11. | Non-citrus fruit juices and tomato juice | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
12. | Fruits | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
13. | Potatoes | 2 | 9 | 0 | 0 | 0 | 0 | 0 | 1 | 3 | 0 | 0 | 0 | 0 | 0
14. | Vegetables and tomatoes | 9 | 22 | 0 | 0 | 0 | 0 | 56 | 1 | 2 | 0 | 0 | 0 | 0 | 6
15. | Fats, oils and dressings | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
16. | Sugars and sweets | 3 | 12 | 0 | 0 | 0 | 0 | 37 | 0 | 1 | 0 | 0 | 0 | 0 | 2
17. | Tea | 253 | 513 | 0 | 0 | 77 | 308 | 848 | 18 | 23 | 0 | 0 | 7 | 26 | 65
18. | Coffee | 200 | 277 | 0 | 0 | 80 | 318 | 955 | 17 | 24 | 0 | 0 | 5 | 30 | 68
19. | Coffee substitutes | 5 | 34 | 0 | 0 | 0 | 0 | 0 | 0 | 2 | 0 | 0 | 0 | 0 | 0
20. | Carbonated soft drinks, regular | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
21. | Carbonated soft drinks, low calorie | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
22. | Non-carbonated soft drinks, regular | 18 | 61 | 0 | 0 | 0 | 0 | 148 | 2 | 5 | 0 | 0 | 0 | 0 | 9
23. | Non-carbonated soft drinks, low calorie | 3 | 17 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0
24. | Beer | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | ’ 0
25. | Wine | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
26. | Spirits, liqueurs, and mixed drinks | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
27. | Baby fruit juice | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
28. | Baby food (excluding baby fruit juice) | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| All Sources | 1310 | 591 | 430 | 855 | 1330 | 1693 | 2191 | 100

§ Individual values may not add to totals due to rounding.

♦ Actual number of observations = 77; weighted number of observations = 151.2.

0 Less than 0.5 g/day or less than 0.5 percent.

Set J. Table 66 Dietary Sources of Tapwater of Male and Female Breast-fed Children (All Ages) (All Regions, All Seasons) ^§♦^+

Sources of Tapwater | | g/day | | | | | | | % of Total g/day
Sources of Tapwater | | Mean^¶^ | Standard Deviation | 5 | 25 | 50 | 75 | 95 | Mean | Standard Deviation | 5 | 25 | 50 | 75 | 95
1. | Drinking water | 110 | 140 | 0 | 0 | 0 | 240 | 320 | 68 | 40 | 0 | 46 | 90 | 100 | 100
2. | Baby formula | 17 | 71 | 0 | 0 | 0 | 0 | 222 | 10 | 29 | 0 | 0 | 0 | 0 | 100
3. | Milk | 0 | 4 | 0 | 0 | 0 | 0 | 0 | 0 | 2 | 0 | 0 | 0 | 0 | 0
4. | Milk drinks | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
5. | Other dairy products | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
6. | Meat, poultry, fish and mixtures thereof | 1 | 4 | 0 | 0 | 0 | 0 | 2 | 2 | 12 | 0 | 0 | 0 | 0 | 6
7. | Eggs and egg dishes | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
8. | Legumes, nuts and seeds | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0
9. | Grains and grain products | 12 | 32 | 0 | 0 | 0 | 0 | 79 | 9 | 21 | 0 | 0 | 0 | 11 | 46
10. | Citrus juices | 7 | 30 | 0 | 0 | 0 | 0 | 61 | 8 | 24 | 0 | 0 | 0 | 0 | 66
11. | Non-citrus fruit juices and tomato juice | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
12. | Fruits | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0
13. | Potatoes | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
14. | Vegetables and tomatoes | 0 | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 3
15. | Fats, oils and dressings | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
16. | Sugars and sweets | 0 | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 1
17. | Tea | 3 | 15 | 0 | 0 | 0 | 0 | 0 | 1 | 5 | 0 | 0 | 0 | 0 | 6
18. | Coffee | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
19. | Coffee substitutes | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
20. | Carbonated soft drinks, regular | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
21. | Carbonated soft drinks, low calorie | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
22. | Non-carbonated soft drinks, regular | 2 | 10 | 0 | 0 | 0 | 0 | 0 | 1 | 3 | 0 | 0 | 0 | 0 | 10
23. | Non-carbonated soft drinks, low calorie | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
24. | Beer | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
25. | Wine | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
26. | Spirits, liqueurs, and mixed drinks | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
27. | Baby fruit juice | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
28. | Baby food (excluding baby fruit juice) | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| All Sources | 153 | 175 | 0 | 0 | 89 | 249 | 468 | 100

§ Contribution of breast milk not included.

♦ Individual values may not add to totals due to rounding.

+ Please see Discussion (Special Problem: Infants) (page 34) regarding limitations of Tapwater estimates for infants <1 year.

¶ Actual number of observations = 100; weighted number of observations = 121.0.

0 Less than 0.5 g/day or less than 0.5 percent.

### K ENERGY INTAKE (kcal/day)

Set K. Table 67 Energy Intake (kcal/day) by Broad Age Category and Sex (All Regions, All Seasons) ^§♦^

Sex | Age (yr) | Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Sex | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Both Sexes | < 1 | 403 | 444.3 | 784 | 237.2 | 11.8 | 263 | 416 | 505 | 618 | 774 | 936 | 1091 | 1193 | 1498
| 1–10 | 5605 | 6354.1 | 1618 | 511.7 | 6.8 | 627 | 860 | 1010 | 1266 | 1565 | 1920 | 2281 | 2527 | 3045
| 11–19 | 5801 | 6824.9 | 2095 | 752.7 | 9.9 | 667 | 1043 | 1241 | 1581 | 2011 | 2489 | 3065 | 3482 | 4359
| 20–64 | 11731 | 21744.9 | 1867 | 740.6 | 6.8 | 552 | 877 | 1048 | 1342 | 1758 | 2270 | 2843 | 3220 | 4116
| 65+ | 2541 | 4142.0 | 1617 | 572.6 | 11.4 | 580 | 832 | 969 | 1233 | 1552 | 1939 | 2331 | 2601 | 3401
| All | 26081 | 39510.2 | 1828 | 716.9 | 4.4 | 553 | 852 | 1029 | 1332 | 1724 | 2212 | 2754 | 3143 | 4023
Males | < 1 | 200 | 219.4 | 792 | 227.9 | 16.1 | * | 454 | 517 | 618 | 786 | 949 | 1065 | 1171 | *
| 1–10 | 2854 | 3223.8 | 1662 | 533.0 | 10.0 | 658 | 891 | 1036 | 1291 | 1605 | 1977 | 2337 | 2617 | 3207
| 11–19 | 2844 | 3363.2 | 2408 | 777.8 | 14.6 | 966 | 1315 | 1513 | 1878 | 2303 | 2840 | 3432 | 3889 | 4673
| 20–64 | 5023 | 9168.1 | 2302 | 760.9 | 10.7 | 915 | 1227 | 1425 | 1786 | 2222 | 2722 | 3255 | 3669 | 4630
| 65+ | 967 | 1698.1 | 1902 | 610.6 | 19.6 | 756 | 1063 | 1209 | 1499 | 1847 | 2221 | 2650 | 2936 | 3786
| All | 11888 | 17672.6 | 2148 | 775.0 | 7.1 | 710 | 1049 | 1251 | 1611 | 2067 | 2568 | 3146 | 3551 | 4492
Females | < 1 | 203 | 225.0 | 777 | 246.2 | 17.3 | * | 411 | 480 | 608 | 757 | 922 | 1116 | 1203 | *
| 1–10 | 2751 | 3130.2 | 1573 | 484.6 | 9.2 | 607 | 838 | 982 | 1242 | 1531 | 1861 | 2208 | 2432 | 2863
| 11–19 | 2957 | 3461.7 | 1788 | 583.3 | 10.7 | 551 | 907 | 1098 | 1398 | 1744 | 2135 | 2513 | 2805 | 3509
| 20–64 | 6708 | 12576.8 | 1548 | 536.3 | 6.5 | 493 | 769 | 928 | 1184 | 1496 | 1850 | 2226 | 2489 | 3117
| 65+ | 1574 | 2443.9 | 1418 | 447.9 | 11.3 | 495 | 740 | 886 | 1097 | 1381 | 1702 | 1995 | 2212 | 2580
| All | 14193 | 21837.6 | 1568 | 541.4 | 4.5 | 505 | 771 | 930 | 1198 | 1518 | 1877 | 2255 | 2516 | 3122

§ Does not include pregnant women, lactating women, or breast-fed children.

♦ Individual values may not add to totals due to rounding.

* Value not reported due to insufficient number of observations.

Set K. Table 68 Energy Intake (kcal/day) by Fine Age Category and Sex (All Regions, All Seasons) ^§♦^

Sex | Age (yr) | Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Sex | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Both Sexes | < 0.5 | 182 | 201.1 | 685 | 220.6 | 16.4 | * | 365 | 454 | 550 | 660 | 776 | 957 | 1072 | *
| 0.5–0.9 | 221 | 243.2 | 867 | 218.4 | 14.7 | * | 517 | 607 | 740 | 866 | 1002 | 1141 | 1216 | *
| 1– 3 | 1498 | 1687.7 | 1271 | 388.8 | 10.0 | 521 | 695 | 807 | 1012 | 1250 | 1488 | 1746 | 1928 | 2366
| 4– 6 | 1702 | 1923.9 | 1553 | 421.8 | 10.2 | 716 | 940 | 1046 | 1265 | 1519 | 1798 | 2107 | 2291 | 2745
| 7–10 | 2405 | 2742.4 | 1877 | 494.8 | 10.1 | 830 | 1178 | 1302 | 1541 | 1829 | 2167 | 2509 | 2756 | 3319
| 11–14 | 2803 | 3146.9 | 2054 | 644.8 | 12.2 | 795 | 1140 | 1308 | 1629 | 1995 | 2400 | 2887 | 3194 | 3981
| 15–19 | 2998 | 3677.9 | 2128 | 832.6 | 15.2 | 600 | 974 | 1168 | 1542 | 2035 | 2580 | 3208 | 3670 | 4604
| 20–44 | 7171 | 13444.5 | 1907 | 771.9 | 9.1 | 557 | 888 | 1051 | 1359 | 1789 | 2331 | 2901 | 3301 | 4274
| 45–64 | 4560 | 8300.4 | 1803 | 682.3 | 10.1 | 551 | 861 | 1044 | 1325 | 1709 | 2184 | 2696 | 3082 | 3875
| 65–74 | 1663 | 2740.2 | 1631 | 566.6 | 13.9 | 580 | 842 | 1002 | 1252 | 1561 | 1948 | 2346 | 2601 | 3521
| >75 | 878 | 1401.8 | 1588 | 583.2 | 19.7 | 545 | 828 | 926 | 1184 | 1514 | 1906 | 2280 | 2587 | 3272
| All | 26081 | 39510.2 | 1828 | 716.9 | 4.4 | 553 | 852 | 1029 | 1332 | 1724 | 2212 | 2754 | 3143 | 4023
Males | <0.5 | 87 | 96.4 | 672 | 195.7 | 21.0 | * | 355 | 454 | 554 | 656 | 776 | 864 | 993 | *
| 0.5–0.9 | 113 | 122.9 | 886 | 206.4 | 19.4 | * | 520 | 647 | 764 | 872 | 1008 | 1116 | 1215 | *
| 1– 3 | 775 | 879.6 | 1317 | 402.4 | 14.5 | 553 | 732 | 843 | 1049 | 1294 | 1520 | 1786 | 1975 | 2580
| 4– 6 | 883 | 991.4 | 1586 | 428.2 | 14.4 | 716 | 948 | 1070 | 1286 | 1546 | 1848 | 2148 | 2316 | 2736
| 7–10 | 1196 | 1352.9 | 1941 | 527.4 | 15.3 | 744 | 1158 | 1322 | 1597 | 1906 | 2234 | 2617 | 2835 | 3389
| 11–14 | 1395 | 1571.8 | 2255 | 668.6 | 17.9 | 1045 | 1314 | 1468 | 1785 | 2186 | 2620 | 3121 | 3499 | 4350
| 15–19 | 1449 | 1791.4 | 2543 | 839.6 | 22.1 | 915 | 1321 | 1567 | 2008 | 2424 | 3002 | 3645 | 4093 | 4944
| 20–44 | 3146 | 5702.7 | 2373 | 784.8 | 14.0 | 963 | 1258 | 1462 | 1829 | 2286 | 2811 | 3347 | 3778 | 4773
| 45–64 | 1877 | 3465.4 | 2186 | 704.7 | 16.3 | 843 | 1163 | 1366 | 1693 | 2117 | 2583 | 3116 | 3436 | 4199
| 65–74 | 656 | 1172.3 | 1913 | 585.8 | 22.9 | 754 | 1080 | 1246 | 1513 | 1856 | 2225 | 2635 | 2937 | 3806
| >75 | 311 | 525.8 | 1878 | 662.4 | 37.6 | * | 950 | 1147 | 1473 | 1780 | 2206 | 2692 | 2892 | *
| All | 11888 | 17672.6 | 2148 | 775.0 | 7.1 | 710 | 1049 | 1251 | 1611 | 2067 | 2568 | 3146 | 3551 | 4492
Females | < 0.5 | 95 | 104.7 | 697 | 241.5 | 24.8 | * | 402 | 429 | 538 | 660 | 783 | 1013 | 1100 | *
| 0.5–0.9 | 108 | 120.2 | 847 | 229.2 | 22.1 | * | 462 | 563 | 713 | 829 | 985 | 1178 | 1216 | *
| 1– 3 | 723 | 808.2 | 1222 | 367.4 | 13.7 | 505 | 645 | 770 | 966 | 1201 | 1446 | 1714 | 1871 | 2178
| 4– 6 | 819 | 932.5 | 1518 | 412.1 | 14.4 | 721 | 930 | 1016 | 1232 | 1482 | 1740 | 2039 | 2271 | 2799
| 7–10 | 1209 | 1389.5 | 1815 | 452.4 | 13.0 | 888 | 1179 | 1285 | 1510 | 1762 | 2078 | 2409 | 2682 | 3082
| 11–14 | 1408 | 1575.1 | 1853 | 551.7 | 14.7 | 579 | 1012 | 1202 | 1483 | 1824 | 2181 | 2519 | 2770 | 3336
| 15–19 | 1549 | 1886.5 | 1734 | 603.3 | 15.3 | 526 | 829 | 1025 | 1346 | 1673 | 2080 | 2489 | 2842 | 3572
| 20–44 | 4025 | 7741.7 | 1563 | 550.5 | 8.7 | 494 | 770 | 927 | 1184 | 1506 | 1871 | 2255 | 2521 | 3205
| 45–64 | 2683 | 4835.1 | 1528 | 512.1 | 9.9 | 493 | 768 | 928 | 1184 | 1482 | 1820 | 2173 | 2437 | 3016
| 65–74 | 1007 | 1567.9 | 1421 | 448.3 | 14.1 | 505 | 725 | 888 | 1104 | 1384 | 1703 | 2000 | 2226 | 2580
| >75 | 567 | 876.0 | 1413 | 447.4 | 18.8 | 495 | 769 | 885 | 1078 | 1370 | 1698 | 1990 | 2200 | 2550
| All | 14193 | 21837.6 | 1568 | 541.4 | 4.5 | 505 | 771 | 930 | 1198 | 1518 | 1877 | 2255 | 2516 | 3122

§ Does not include pregnant women, lactating women, or breast-fed children.

♦ Individual values may not add to totals due to rounding.

* Value not reported due to insufficient number of observations.

Set K. Table 69 Energy Intake (kcal/day) of Pregnant Women, Lactating Women, and Breast-fed Children (All Regions, All Seasons)

| Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
| Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 5 | 10 | 25 | 50 | 75 | 90 | 95
Pregnant women | 188 | 327.5 | 1719 | 555.7 | 40.5 | 917 | 1124 | 1362 | 1617 | 2051 | 2474 | 2782
Lactating women | 77 | 151.2 | 1887 | 625.5 | 71.3 | 954 | 1067 | 1457 | 1856 | 2275 | 2585 | 2951
Breast-fed children^§^
Both sexes
All ages | 100 | 121.0 | 282 | 290.2 | 29.0 | 0 | 0 | 10 | 203 | 436 | 689 | 895
< 0.5 yr | 62 | 74.4 | 178 | 223.9 | 28.4 | * | 0 | 0 | 57 | 350 | 518 | *
≥ 0.5 yr | 38 | 46.6 | 450 | 307.2 | 49.8 | * | 85 | 203 | 394 | 641 | 895 | *
Males
All ages | 42 | 49.4 | 287 | 285.2 | 44.0 | * | 0 | 10 | 278 | 427 | 720 | *
< 0.5 yr | 28 | 34.0 | 197 | 244.4 | 46.2 | * | * | 0 | 88 | 350 | * | *
≥ 0.5 yr | 14 | 15.5 | * | * | * | * | * | 335 | 436 | 689 | * | *
Females
All ages | 58 | 71.6 | 279 | 295.6 | 38.8 | * | 0 | 16 | 203 | 442 | 669 | *
< 0.5 yr | 34 | 40.5 | 161 | 206.8 | 35.5 | * | * | 0 | 47 | 274 | * | *
≥ 0.5 yr | 24 | 31.1 | * | * | * | * | * | 184 | 314 | 628 | * | *

§ Energy intake of breast-fed children does not include the contribution of breast milk.

* Value not reported due to insufficient number of observations.

0 Less than 0.5 kcal/day.

### L SELF-REPORTED WEIGHT (kg)

Set L. Table 70 Self-Reported Weight (kg) by Broad Age Category and Sex (All Regions, All Seasons) ^§♦^

Sex | Age (yr) | Number of Observations | | Standard Mean Deviation | | Standard Error of the Mean | Percentile Distribution
Sex | Age (yr) | Actual Count | Weighted Count | Standard Mean Deviation | | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Both Sexes | < 1 | 403 | 444.3 | 7.7 | 2.5 | 0.1 | 2.7 | 3.6 | 4.1 | 5.9 | 7.7 | 9.1 | 10.9 | 11.8 | 14.5
| 1–10 | 5605 | 6354.1 | 23.1 | 9.1 | 0.1 | 9.5 | 11.3 | 12.7 | 15.9 | 21.8 | 28.6 | 36.3 | 40.4 | 49.0
| 11–19 | 5801 | 6824.9 | 55.2 | 13.4 | 0.2 | 28.6 | 34.0 | 38.6 | 45.4 | 54.4 | 63.5 | 72.6 | 79.4 | 91.6
| 20–64 | 11731 | 21744.9 | 70.5 | 15.2 | 0.1 | 44.5 | 49.9 | 52.2 | 59.0 | 68.0 | 79.8 | 90.7 | 97.5 | 113.4
| 65+ | 2541 | 4142.0 | 68.6 | 13.1 | 0.3 | 40.8 | 48.5 | 52.2 | 59.0 | 68.0 | 77.1 | 84.8 | 90.7 | 103.4
| All | 26081 | 39510.2 | 59.3 | 22.6 | 0.1 | 9.1 | 15.9 | 22.7 | 48.5 | 61.2 | 74.8 | 86.2 | 90.7 | 108.9
Males | < 1 | 200 | 219.4 | 8.1 | 2.6 | 0.2 | * | 4.1 | 4.5 | 6.4 | 8.2 | 9.1 | 11.3 | 12.7 | *
| 1–10 | 2854 | 3223.8 | 23.2 | 9.2 | 0.2 | 10.0 | 11.3 | 13.2 | 15.9 | 21.8 | 28.6 | 36.3 | 40.8 | 49.9
| 11–19 | 2844 | 3363.2 | 58.3 | 14.9 | 0.3 | 29.0 | 34.0 | 38.6 | 47.2 | 59.0 | 68.0 | 77.1 | 82.6 | 95.3
| 20–64 | 5023 | 9168.1 | 79.4 | 13.0 | 0.2 | 54.4 | 61.2 | 64.0 | 70.3 | 78.0 | 86.2 | 95.3 | 103.4 | 117.9
| 65+ | 967 | 1698.1 | 74.4 | 11.5 | 0.4 | 49.9 | 56.7 | 61.2 | 67.1 | 73.9 | 81.6 | 89.8 | 95.3 | 104.3
| All | 11888 | 17672.6 | 63.8 | 25.3 | 0.2 | 9.1 | 15.4 | 20.9 | 49.9 | 70.3 | 81.6 | 90.7 | 97.5 | 112.5
Females | < 1 | 203 | 225.0 | 7.2 | 2.4 | 0.2 | * | 3.6 | 3.6 | 5.4 | 7.3 | 9.1 | 10.0 | 11.3 | *
| 1–10 | 2751 | 3130.2 | 22.9 | 9.1 | 0.2 | 9.1 | 11.3 | 12.7 | 15.9 | 21.8 | 28.6 | 36.3 | 39.5 | 47.6
| 11–19 | 2957 | 3461.7 | 52.1 | 11.0 | 0.2 | 28.1 | 34.0 | 38.6 | 45.4 | 52.2 | 57.2 | 63.5 | 70.8 | 86.2
| 20–64 | 6708 | 12576.8 | 64.1 | 13.4 | 0.2 | 43.1 | 47.6 | 49.9 | 54.4 | 61.2 | 70.3 | 81.6 | 89.8 | 108.9
| 65+ | 1574 | 2443.9 | 64.5 | 12.6 | 0.3 | 39.9 | 45.4 | 49.9 | 55.8 | 63.5 | 72.6 | 81.2 | 86.2 | 103.4
| All | 14193 | 21837.6 | 55.7 | 19.5 | 0.2 | 9.1 | 15.9 | 24.9 | 48.1 | 56.7 | 66.7 | 77.1 | 86.2 | 103.4

§ Does not include pregnant women, lactating women, or breast-fed children.

♦ Individual values may not add to totals due to rounding.

* Value not reported due to insufficient number of observations.

Set L. Table 71 Self-Reported Weight (kg) by Fine Age Category and Sex (All Regions, All Seasons) ^§♦^

Sex | Age (yr) | Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
Sex | Age (yr) | Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 1 | 5 | 10 | 25 | 50 | 75 | 90 | 95 | 99
Both Sexes | < 0.5 | 182 | 201.1 | 5.8 | 1.8 | 0.1 | * | 3.2 | 3.6 | 4.5 | 5.4 | 6.8 | 8.2 | 8.6 | *
| 0.5–0.9 | 221 | 243.2 | 9.2 | 2.0 | 0.1 | * | 6.8 | 7.3 | 8.2 | 9.1 | 10.0 | 11.3 | 13.6 | *
| 1– 3 | 1498 | 1687.7 | 14.1 | 3.2 | 0.1 | 8.6 | 10.0 | 10.4 | 11.8 | 13.6 | 15.9 | 18.1 | 20.4 | 24.5
| 4– 6 | 1702 | 1923.9 | 20.3 | 4.6 | 0.1 | 12.7 . | 13.6 | 15.4 | 17.2 | 20.0 | 22.7 | 26.8 | 28.6 | 36.3
| 7–10 | 2405 | 2742.4 | 30.6 | 7.8 | 0.2 | 18.1 | 20.4 | 22.7 | 24.9 | 29.5 | 34.5 | 40.8 | 44.9 | 54.4
| 11–14 | 2803 | 3146.9 | 47.7 | 11.2 | 0.2 | 27.2 | 31.8 | 34.0 | 40.4 | 46.7 | 54.4 | 61.2 | 67.6 | 81.6
| 15–19 | 2998 | 3677.9 | 61.6 | 11.8 | 0.2 | 40.8 | 45.4 | 48.1 | 52.6 | 59.0 | 68.0 | 77.1 | 83.9 | 95.3
| 20–44 | 7171 | 13444.5 | 69.4 | 15.4 | 0.2 | 44.0 | 49.0 | 52.2 | 57.2 | 68.0 | 79.4 | 89.8 | 96.2 | 113.4
| 45–64 | 4560 | 8300.4 | 72.4 | 14.7 | 0.2 | 45.4 | 51.3 | 54.4 | 61.2 | 71.7 | 81.6 | 90.7 | 98.4 | 113.4
| 65–74 | 1663 | 2740.2 | 70.1 | 13.2 | 0.3 | 44.9 | 49.9 | 53.5 | 61.2 | 70.3 | 78.0 | 86.2 | 90.7 | 104.3
| >75 | 878 | 1401.8 | 65.5 | 12.3 | 0.4 | 38.6 | 45.4 | 49.9 | 57.2 | 65.8 | 72.6 | 81.6 | 86.2 | 95.3
| All | 26081 | 39510.2 | 59.3 | 22.6 | 0.1 | 9.1 | 15.9 | 22.7 | 48.5 | 61.2 | 74.8 | 86.2 | 90.7 | 108.9
Males | < 0.5 | 87 | 96.4 | 6.2 | 1.8 | 0.2 | * | 3.6 | 3.6 | 5.0 | 6.4 | 7.3 | 8.2 | 9.1 | *
| 0.5–0.9 | 113 | 122.9 | 9.6 | 2.1 | 0.2 | * | 6.8 | 7.3 | 8.2 | 9.1 | 10.4 | 12.2 | 13.6 | *
| 1– 3 | 775 | 879.6 | 14.4 | 3.3 | 0.1 | 9.1 | 10.0 | 10.9 | 12.2 | 13.6 | 15.9 | 18.1 | 20.4 | 24.9
| 4– 6 | 883 | 991.4 | 20.5 | 4.5 | 0.2 | 13.6 | 14.5 | 15.9 | 18.1 | 20.4 | 22.7 | 27.2 | 29.5 | 36.3
| 7–10 | 1196 | 1352.9 | 31.0 | 7.9 | 0.2 | 18.1 | 20.9 | 22.7 | 24.9 | 29.5 | 35.4 | 40.8 | 45.4 | 54.4
| 11–14 | 1395 | 1571.8 | 48.2 | 11.8 | 0.3 | 27.2 | 31.8 | 34.0 | 39.9 | 46.7 | 55.8 | 63.5 | 68.0 | 81.6
| 15–19 | 1449 | 1791.4 | 67.3 | 11.3 | 0.3 | 43.1 | 49.9 | 54.4 | 59.0 | 65.8 | 73.0 | 81.6 | 88.0 | 99.8
| 20–44 | 3146 | 5702.7 | 78.8 | 12.9 | 0.2 | 54.4 | 61.2 | 63.5 | 70.3 | 77.1 | 86.2 | 95.3 | 102.1 | 117.9
| 45–64 | 1877 | 3465.4 | 80.4 | 12.9 | 0.3 | 52.2 | 61.7 | 65.8 | 72.6 | 79.4 | 86.2 | 97.5 | 104.3 | 113.4
| 65–74 | 656 | 1172.3 | 75.8 | 11.7 | 0.5 | 49.9 | 58.5 | 62.6 | 68.0 | 74.8 | 81.6 | 90.7 | 97.5 | 106.6
| >75 | 311 | 525.8 | 71.1 | 10.3 | 0.6 | * | 54.4 | 59.0 | 64.0 | 70.3 | 77.1 | 86.2 | 90.7 | *
| All | 11888 | 17672.6 | 63.8 | 25.3 | 0.2 | 9.1 | 15.4 | 20.9 | 49.9 | 70.3 | 81.6 | 90.7 | 97.5 | 112.5
Females | < 0.5 | 95 | 104.7 | 5.5 | 1.8 | 0.2 | * | 2.7 | 3.6 | 4.1 | 5.4 | 6.8 | 7.3 | 8.6 | *
| 0.5–0.9 | 108 | 120.2 | 8.8 | 1.7 | 0.2 | * | 6.8 | 6.8 | 7.7 | 8.6 | 9.5 | 11.3 | 12.7 | *
| 1– 3 | 723 | 808.2 | 13.7 | 3.0 | 0.1 | 8.6 | 9.5 | 10.0 | 11.3 | 13.6 | 15.9 | 18.1 | 19.5 | 23.1
| 4– 6 | 819 | 932.5 | 20.0 | 4.6 | 0.2 | 12.7 | 13.6 | 15.0 | 17.2 | 19.1 | 22.7 | 25.9 | 28.1 | 35.8
| 7–10 | 1209 | 1389.5 | 30.2 | 7.6 | 0.2 | 18.1 | 20.4 | 21.8 | 24.9 | 29.5 | 34.0 | 40.8 | 44.0 | 54.4
| 11–14 | 1408 | 1575.1 | 47.2 | 10.6 | 0.3 | 27.2 | 31.8 | 34.0 | 40.8 | 46.3 | 54.0 | 59.0 | 64.0 | 79.4
| 15–19 | 1549 | 1886.5 | 56.2 | 9.5 | 0.2 | 40.8 | 44.5 | 46.3 | 49.9 | 54.4 | 60.8 | 68.0 | 73.5 | 90.7
| 20–44 | 4025 | 7741.7 | 62.5 | 13.3 | 0.2 | 42.6 | 47.2 | 49.9 | 54.0 | 59.0 | 68.0 | 80.7 | 88.5 | 108.9
| 45–64 | 2683 | 4835.1 | 66.6 | 13.2 | 0.3 | 44.0 | 49.9 | 52.2 | 57.2 | 63.5 | 72.6 | 83.9 | 90.7 | 106.6
| 65–74 | 1007 | 1567.9 | 65.9 | 12.6 | 0.4 | 41.7 | 47.6 | 49.9 | 57.2 | 63.5 | 72.6 | 81.6 | 88.5 | 103.9
| >75 | 567 | 876.0 | 62.1 | 12.2 | 0.5 | 38.6 | 43.5 | 47.6 | 54.4 | 61.2 | 68.9 | 77.1 | 81.6 | 99.8
| All | 14193 | 21837.6 | 55.7 | 19.5 | 0.2 | 9.1 | 15.9 | 24.9 | 48.1 | 56.7 | 66.7 | 77.1 | 86.2 | 103.4

§ Does not include pregnant women, lactating women, or breast-fed children.

♦ Individual values may not add to totals due to rounding.

* Value not reported due to insufficient number of observations.

Set L. Table 72 Self-Reported Weight (kg) of Pregnant Women, Lactating Women, and Breaet-fed Children (All Regions, All Seasons)

| Number of Observations | | Mean | Standard Deviation | Standard Error of the Mean | Percentile Distribution
| Actual Count | Weighted Count | Mean | Standard Deviation | Standard Error of the Mean | 5 | 10 | 25 | 50 | 75 | 90 | 95
Pregnant women | 188 | 327.5 | 65.8 | 10.6 | 0.8 | 49.9 | 53.5 | 59.0 | 64.4 | 72.6 | 77.6 | 64.4
Lactating women | 77 | 151.2 | 61.9 | 12.4 | 1.4 | 49.9 | 49.9 | 54.4 | 59.0 | 64.9 | 77.1 | 81.6
Breast-fed children
Both sexes
All ages | 100 | 121.0 | 6.9 | 2.1 | 0.2 | 4.1 | 4.5 | 5.0 | 6.8 | 8.2 | 9.5 | 10.9
< 0.5 yr | 62 | 74.4 | 5.8 | 1.5 | 0.2 | * | 4.1 | 4.5 | 5.4 | 6.8 | 6.2 | *
≥ 0.5 yr | 36 | 46.6 | 8.7 | 1.8 | 0.3 | * | 6.8 | 7.3 | 8.2 | 10.0 | 11.3 | *
Males
All ages | 42 | 49.4 | 7.0 | 2.2 | 0.3 | * | 4.5 | 5.0 | 6.8 | 8.2 | 9.1 | *
< 0.5 yr | 28 | 34.0 | 6.0 | 1.5 | 0.3 | * | * | 4.5 | 5.9 | 7.3 | * | *
≥ 0.5 yr | 14 | 15.5 | * | * | * | * | * | 7.7 | 9.1 | 10.0 | * | *
Females
All ages | 58 | 71.6 | 6.8 | 2.1 | 0.3 | * | 4.1 | 5.0 | 6.8 | 7.7 | 10.0 | *
< 0.5 yr | 34 | 40.5 | 5.6 | 1.5 | 0.3 | * | * | 4.5 | 5.0 | 6.8 | * | *
≥ 0.5 yr | 24 | 31.1 | * | * | * | * | * | 7.3 | 7.7 | 9.1 | * | *

* Value not reported due to insufficient number of observations.

## B QUANTITIES OF TOTAL WATER AND TAPWATER CONSUMED

### 1 Total Water Intake (g/day) (see Table Set A)

The distribution of Total Water intake in the study population is shown in Figure 3a. Average consumption by all age groups (n=26,081) was 2,072 ± 803 g/day from all sources, including foods, beverages, and drinking water. The skewed distribution is the consequence of combining data from infants, children, and adults but also reflects a small number of adult subjects who consumed very large quantities. It is more instructive to examine intake of different age groups. As expected, the distribution of intake shifts to the right (upwards) with increasing age (Figure 3b). Virtually all infants (<1 year) and children (1–10 years) consumed under 3,000 g/day, whereas 9% of adolescents (11–19 years) and 13–16% of adults (20+ years) consumed over this amount.

### 2 Tapwater Intake (g/day) (see Table Set D)

Similar skewing is evident in the distribution of Tapwater intake of the study population (Figure 4a). Mean Tapwater intake from drinking water and tapwater added during preparation of beverages and foods was 1,193 ± 702 g/day. In the whole study population, 88% consumed 2,000 g/day or less, 10% consumed 2,000–2,999 g/day and 2% consumed over g/day. No infants (<1 year) and only 0.8% of children consumed more than g/day. With increasing age, however, more people ingested tapwater in excess of 2,000 g/day, reaching nearly 18% of adults 65+ years; 3% of adults 20–64 years consumed 3,000 g/day or more (Figure 4b).

### 3 Effects of Sex in Relation to Water Intake

As expected, males generally had higher mean intakes than females. This difference was significant (p <.05) by analysis of variance for both Total Water (Figure 5a) and Tapwater (Figure 5b) for all age groups over 1 year after adjusting for race, region, season, region x season interaction, body weight, urban residence, and age.

FIGURE 3 DISTRIBUTION OF TOTAL WATER INTAKE (g/day) OF STUDY SUBJECTS

3a. ALL AGES^1^

^1^ Does not include pregnant women, lactating women, or breast-fed children.

3b. BY AGE GROUP^1^

^2^ Values may not add to 100.0% due to rounding.

FIGURE 4 DISTRIBUTION OF TAPWATER INTAKE (g/day) OF STUDY SUBJECTS

4a. ALL AGES^1^

4b. BY AGE GROUP^1^

^1^ Does not include pregnant women, lactating women, or breast-fed children.

^2^ Values may not add to 100.0% due to rounding.

FIGURE 5 MEAN DAILY INTAKE OF TOTAL WATER AND TAPWATER (g/day) BY AGE AND SEX

5a. TOTAL WATER

5b. TAPWATER

### 4 Total Water and Tapwater Intake Expressed per Kilogram Body Weight (see Table Sets B and E)

When expressed per kg body weight, mean Total Water intake showed a smooth exponential decline with increasing age (Figure 6a). This finding was predicted because water requirements generally reflect body composition and metabolic rate, which is high in infancy and declines gradually over childhood to stabilize after adolescence. Tapwater intake, which varies more with choices of source of water, does not show such a smooth decline with age (Figure 6b).

### 5 Effects of Region and Season in Relation to Water Intake

Regional variation in Total Water intake was significant for all groups over 1 year of age (Figure 7a). Intake was lowest in the Northeast and highest in the West. Subjects living in the South generally consumed the highest fraction of their Total Water as Tapwater (59%), whereas this fraction was lowest (51%) in the Northeast. The magnitude of seasonal variations was not as large as regional differences. Intake of both Total Water and Tapwater was highest in the summer and generally lowest in the winter, but the seasonal trends were not consistent across the various age groups (Figure 7b). We expected marked interactions between region and season, but these effects generally were independent and little interaction was observed.

## C SOURCES OF TOTAL WATER AND TAPWATER (see Table Sets G–J) (also see Appendix D)

A relatively small number of beverage and food items accounted for much of the Total Water and Tapwater intake in most age groups (Figure 8). Drinking water, baby formula, milk/milk drinks and juices accounted for 78% of Total Water and 87% of Tapwater consumed by infants under 1 year of age. Carbonated beverage use peaked in adolescents and declined thereafter. The intake of coffee and tea in the 20–64 year age group was similar to that of the 65+ year age group.

Juices were widely consumed but on average did not represent more than 4–7% of Total Water intake. These food items were more important in. the diets of infants, children, and adolescents, representing 10–14% of Tapwater consumed by these groups.

The contribution of foods (including soups) was surprisingly consistent across all age groups, representing 21–29% of Total Water and 8–15% of Tapwater. Soups, which are not described separately in the Tables, comprised about 3% of Total Water and 3% of Tapwater. Average intake of soup was 10, 35, 31, 40, and 53 g Total Water/day and 4, 20, 17, 21, and 28 g Tapwater/day for the <1, 1–10, 11–19, 20–64, and 65+ age groups, respectively.

The milk- or formula-based diet of infants (<1 year) and high coffee and tea intake of adults (20+ years) were responsible for the early and late peaks in Total Water intake expressed in terms of energy intake (g/kcal/day) (Table Set C).

FIGURE 6 MEAN TOTAL WATER AND TAPWATER INTAKE PER UNIT BODY WEIGHT (g/kg/day) BY AGE AND SEX

6a. TOTAL WATER

6b. TAPWATER

FIGURE 7 MEAN TOTAL WATER INTAKE (g/day) BY SOURCE FOR REGION OR SEASON AND AGE

7a. REGION

7b. SEASON

FIGURE 8 DIETARY SOURCES OF TOTAL WATER AND TAPWATER BY AGE

8a. TOTAL WATER

8b. TAPWATER