# IV METHODS: STATISTICAL PROCEDURES

## A COMPUTER SOFTWARE

The SAS software package (Harrell, 1983; SAS User's Guide, 1985) was used for all statistical analyses as well as the data management activities described in Chapter III.

## B DELETION OF OUTLIERS

After the final water intake database was created (Figure 2, Step 25), the total water intake of 35 individuals (0.1% of the subjects who had complete data) was found to exceed 6 standard deviations from the age-stratum-specific mean. Records of these subjects suggested coding or reporting errors that yielded improbable values for cups of water drunk (omission of decimal points, substitution of ounces for cups); body weight; or quantities of foods and beverages consumed. These subjects were therefore deleted from the data set to eliminate their distorting effect on the planned analysis of variance. Subjects were not deleted because of illness or low intake unless they reported that they were fasting.

## C FINAL SAMPLE SIZE

The final database used to generate the Tables contained observations from 26,446 subjects after deletion of the 4,289 subjects with incomplete data and the 35 outliers.

## D USE OF 3-DAY AVERAGES

The methodology for the 24-hour recall (first day's data) and the 2-day diet record (second and third days' data) was pre-tested and validated in studies conducted for the USDA (Response Analysis Corporation, 1976), although the question regarding cups of water drunk each day was not evaluated separately. NFCS interviewers provided training and instructions to the study subjects for the 2-day diet record so that the subjects would better document the quantities of foods and all other beverages consumed. The internal consistency of the data suggests that this training was also effective for the question on cups of water drunk.

The overall mean intakes of Total Water (2,109, 2,048, and 2,046 g/day) and Tapwater (1,213, 1,180, and 1,178 g/day) on Days 1, 2, and 3, respectively, differed by less than 3% between Day 1 and Day 2 or Day 3 (n=26,446), indicating that the 24-hour recall and the 2-day diet record yielded similar results. Furthermore, the variance of the 3-day average of Total Water or Tapwater intake was approximately 75% of the variance for Day 1 alone or any single randomly chosen day. Between-individuals variation accounted for approximately 62% of the variance in Total Water or Tapwater intake.

Taken together, these results indicate that individuals do tend to consume similar quantities of water on three successive days, but that considerably more stable estimates of individual and population intakes are obtained by using 3-day averages. This approach is consistent with that used by the USDA for estimating intakes of other nutrients (U.S. Department of Agriculture, 1984).

## E WEIGHTING FACTORS

The general purpose of survey research is to characterize a large population by careful study of a sample drawn from that population. The study sample often does not represent all of the underlying population's subgroups in appropriate proportion. Weighting factors (or "weights") reflect the differing representation of these subgroups in the study sample and are used in subsequent calculations to ensure that the results correctly describe the underlying population (Snedecor and Cochran, 1987).

All calculations and statistical procedures used in this report incorporated a combined weighting factor that was the product of two weighting factors from the USDA and NCI segments of this study:

### 1 USDA Weighting Factor

The USDA weighting factor was based upon numbers of completed interviews in primary sampling units (PSU). The following is excerpted from USDA documentation (U.S. Department of Agriculture, 1984): "The 48 conterminous States were divided into 114 strata on the basis of three levels of stratifications - geographic division, urbanization or zone, and demographic or other geographic similarities . . . Every stratum was divided into one or more PSU. The PSUs were formed from cities, parts of cities, or from counties and each contained at least 10,000 housing units." "Although the household survey was designed to be self-weighting, it was determined . . . that the completion rates for the various PSUs differed at a statistically significant level. Therefore, weighting factors were applied to data from completed schedules. The weights were calculated for each quarter for every PSU. The weights were designed to be proportional to the ratio of the expected number of completed schedules in a PSU to the collected number of completed schedules in a PSU; . . . The weight factor applied to the household was also applied to the records of every individual in that household."

### 2 NCI Weighting Factor

Each individual on the final Water Intake Database (Figure 2, Step 25) was assigned a weighting factor reflecting the proportion of outliers or subjects with incomplete data deleted from each age/sex/region/season/race-specific stratum.

The role of the Combined Weighting Factor in the SAS algorithms used to generate the Tables is described in Appendix A.

Appendix E demonstrates how well the age, sex, and race distribution of the underlying 1977 U.S. population (National Cancer Institute, 1981) is mirrored by the weighted study sample.

## F DESIGN EFFECT

The 1977–78 NFCS actually sampled not individuals but households, which are drawn from clusters of 100+ housing units ("area segments") within larger clusters of 10,000 housing units ("primary sampling units") (U.S. Department of Agriculture, 1984). Persons living in the same household may have more similar dietary habits than persons living in different households, and their intakes of water may also be similarly correlated.

The cumulative result of the various layers of clustering described above is the "design effect" of the survey. It is desirable to account for the design effect when calculating the variance for the study population. There are no published estimates, however, for the 1977–78 NFCS design effect, nor could we make such an estimate with the information available to us. Given the lack of specific information on the magnitude of the design effect for this particular survey, we have assumed it to equal 1.0. It is possible, however, that the inability to make this adjustment has led us to underestimate the variance of water intake.

## G CALCULATION OF DESCRIPTIVE STATISTICS

Algorithms for the following are found in Appendix A.

### 1 Mean, Variance, and Standard Deviation

The weighted mean, variance, and standard deviation were calculated using SAS PROC MEANS with the WDF option (SAS User's Guide, 1985).

### 2 Standard Error

The standard error was calculated separately as the weighted standard deviation divided by the square root of the actual (unweighted) sample size.

### 3 Percentiles

The weighted percentile distribution was calculated using PROC PCTL (Harrell, 1983).

## H GUIDELINES FOR REPORTING DESCRIPTIVE STATISTICS

### 1 Minimum Required Sample Sizes

Reliable estimates must be based on sufficient numbers of observations. Using guidelines developed by the National Center for Health Statistics (Casady, 1982a,b; National Center for Health Statistics, 1982), we required that the following minimum sample sizes of interviewed subjects be met for presenting data:

Descriptive Statistic | Minimum Sample Size
Mean | 25
Standard Deviation and Standard Error | 25
50th Percentile (median) | 6
25th and 75th Percentiles | 13
10th and 90th Percentiles | 36
5th and 95th Percentiles | 72
1st and 99th Percentiles | 369

### 2 Applying Minimal Sample Size Guidelines to the Tables of Water Intake Data

Our study sample is large enough to provide reliable estimates of the 1st and 99th percentiles of intake for nearly all demographic subgroups presented in the Tables. However, pregnant women, lactating women, breast-fed children, and some subgroups of the <1 year and 65+ years age categories were exceptions in that criteria on minimal sample size were not met.

### 3 Notation of Insufficient Sample Size

An asterisk (*) is used in the Tables when the unweighted number of observations for a population subgroup is not sufficient for a reliable estimate of the mean, standard deviation, standard error, or a particular percentile.

### 4 Role of "Design Effect" in Establishing Minimum Required Sample Size

The values in section H-1 represent minimum sample sizes for situations in which the "design effect" is equal to or close to 1.0. Larger design effects would increase the minimum sample size requirement for a particular estimate. For this report, we have assumed that the design effect is equal to 1.0.

## I ROUNDING PROCEDURES

The SAS software package (SAS User's Guide, 1985) uses the conventional practice of rounding "down" for digits 1–4 and rounding "up" for digits 5–9.

Data in the percentile distributions in the Tables are rounded as follows. An extra decimal point is reported for the mean or standard deviation in some of the Tables.

Variable | Units | Rounded to the Nearest
Total Water or Tapwater Intake | g/day | g
Total Water or Tapwater Intake | g/kg/day | 0.1 g/kg
Total Water Intake | g/kcal/day | 0.1 g/kcal
Tapwater Intake | % of total/day | 0.1 percent
Dietary Sources of Total Water or Tapwater | g/day | g
Dietary Sources of Total Water or Tapwater | %/day | percent
Energy Intake | kcal | kcal
Weight | kg | 0.1 kg

## J UNITS OF MEASUREMENT

### 1 Use of Weight Units

The data presented in the Tables are expressed in weight units (grams) rather than in volume units (liters or milliliters) as in some other reports (Canada, Environmental Health Directorate, 1981; Hopkin and Ellis, 1980; Sharrett et al., 1982). We have calculated Total Water and Tapwater intake on a weight basis in accord with the original data from which these estimates were derived:

- Individual Food Intake File (Figure 2, Step 1). Portion sizes of foods and beverages consumed are expressed in grams.
- Nutrient Database File (Figure 2, Step 7). Water content of foods and beverages is expressed in grams per 100 grams edible portion.

### 2 Conversion from Weight to Volume Units

Over the typical range of temperatures at which food is consumed, the relative density of water is 1.0 g/ml (Hodgman et al., 1958). This figure may be used by readers wishing to convert from weight to volume units.

## K DEMOGRAPHIC AND OTHER CATEGORIES USED IN THE TABLES

It would be cumbersome to present tables of data for every conceivable demographic or other subset of the study population. To determine which "breakdown" categories we would use, demographic variables of high a priori interest were chosen and an analysis of variance for unbalanced designs (SAS PROC GLM) was conducted (SAS User's Guide, 1985).

The a priori model set total water intake (g/day) as the dependent variable. The model included sex, race, region, season, and urbanization as main effects; region x season interaction; and age, body weight, and mean educational level of heads of household as covariates. Education served as a surrogate for household income because many subjects (23%) did not report income. This model was used separately for eight groups: Broad Age groupings <1 year, 1–10 years, 11–19 years, 20–64 years, and 65+ years; pregnant women; lactating women; and breast-fed children.

Sex, region, and season were chosen as the main demographic breakdown categories for the Tables of Total Water and Tapwater Intake because they were statistically significant main effects for at least half of the eight groups and also showed consistent ranking patterns. For example, Total Water intake generally was higher in males, in the West, and in the summer. Region x season interaction, urban vs. rural residence, and race did not fit these criteria.

Fine Age groupings were made in an effort to eliminate significant effects of age from the <1, 1–10, 11–19, 20–64, and 65+ year Broad Age groupings, and to define age categories within which Total Water intake was relatively homogenous.

Because of the a priori interest in the effects of age on distribution of various dietary sources of Tapwater and Total Water intake, data are presented in the Tables for the Broad Age categories, breast-fed children, as well as pregnant and lactating women. Data on distributions by sex, region, and season are available, but are not presented in tabular form.