# III METHODS: ESTIMATION OF WATER INTAKE

## A INTRODUCTION

A flow diagram representing the steps in deriving estimates of water intake from the original USDA data files is shown in Figure 2.

## B SOURCES OF DATA: DESCRIPTIONS OF ORIGINAL DATA FILES

The 1977–78 Nationwide Food Consumption Survey (NFCS) conducted by the U.S. Department of Agriculture (USDA) collected data on the intake of foods, beverages, and drinking water in a sample of the U.S. population. Three data files from this survey were used in our analysis.

1. Survey of food intake of individuals in the United States, 1977–78 (abbreviated name: "Individual Food Intake File") (see Figure 2, Step 1).
  The USDA conducted the sixth Nationwide Food Consumption Survey (NFCS) in 1977–78. The computerized data file from the Basic (i.e., all income levels) Survey contains demographic information and records of food and beverage intake for 30,770 individuals living in the 48 states of the continental United States and the District of Columbia (U.S. Department of Agriculture, 1980-1981; U.S. Department of Agriculture, 1988). These individuals constituted a stratified random sample designed to represent the noninstitutionalized U.S. population living in households (U.S. Department of Agriculture, 1984). A questionnaire regarding weekly food purchases and consumption was completed for each participating household. Individual subjects living in the household were then given an interview that included a 24-hour dietary recall and then completed a dietary record for the two subsequent days. Separate questions inquired about the number of 8-fluid-ounce cups of water consumed each day. Each food and beverage item consumed was identified with a 7-digit food code (see Food Code Descriptions file, below) and the portion size was recorded in common household units and later converted to grams. Demographic data included age, sex, race, education of female and male heads of household, urban or rural residence, occupation, and income. Height and weight information were collected by self-report. The interview did not obtain information on physical activity, smoking habits, or specific medical conditions.
  Seventy-two percent of the 14,930 households contacted participated in the household food consumption component of the study, and at least 1 day's dietary data were collected for 94% of eligible individuals living in participating households (U.S. Department of Health and Human Services, and U.S. Department of Agriculture, 1986). Thus the overall participation rate for individuals was 68%.
  The survey took place throughout the year; approximately equal proportions of subjects in each region were interviewed in the spring, summer, fall, and winter.
  Data were collected for all days of the week, although weekend days were underrepresented compared to mid-week days; 19.5% of dietary interviews and records were collected for Saturday and Sunday and 80.5% for Monday through Friday (U.S. Department of Agriculture, 1984).
2. Manual of food codes and conversions of measures to gram-weight for use with individual food intake data from the 1977–78 Nationwide Food Consumption Survey (U.S. Department of Agriculture, 1979) (abbreviated name: "Food Code Descriptions File") (see Figure 2, Step 5).
  This USDA manual matches the 7-digit food codes used in the Individual Food Intake File with fully worded descriptions of 4,545 food and beverage items (U.S. Department of Agriculture, 1979). Gram-weight conversion factors for commonly reported portions of the food items are also provided on the file.
3. Nutrient database for individual food intake surveys (abbreviated name: "Nutrient Database File") (see Figure 2, Step 7).
  This file contains the nutrient content (protein, fat, carbohydrate, vitamins, and minerals) of each of the 4,545 food items reported as consumed in the 1977–78 NFCS (U.S. Department of Agriculture, 1980; U.S. Department of Agriculture, 1988). Data are expressed per 100 grams wet weight of food. This database file does not contain information on the water (moisture) or total ash content of the foods.

FIGURE 2 FLOWCHART: STEPS IN DERIVATION OF WATER INTAKE VARIABLES AND CREATION OF WATER INTAKE DATABASE

## C DEVELOPMENT OF THE WATER INTAKE DATABASE

Figure 2 describes the major steps in the creation of the Water Intake Database that was used to generate the Tables presented in this report. These steps are grouped in 3 major stages:

Stage | Description | Steps Identified in Figure 2
1. | Selecting the Study Sample | 1–4
2. | Calculating Total Water, Intrinsic Water, and Tapwater Content of Foods | 5–10
3. | Creating the Water Intake Database | 11–25

### Stage 1 Selecting the Study Sample (Figure 2. Steps 1–4)

The original study sample on the Individual Food Intake File (Step 1) included 30,770 individuals. From the Individual Food Intake File we selected a subset of variables for this analysis (Step 2): food and beverage items consumed (7-digit code and quantities consumed each day); cups of water drunk each day (drinking water); age, sex, and race; geographic region and urbanization of residence; height and weight; education of heads of household; income; season of interview; and pregnancy/lactation status.

Because we wanted to calculate for each individual a 3-day average intake of Total Water and Tapwater, we eliminated from our analysis (Step 3) subjects who lacked 3 days' data on food and beverage intake (n=2,313) or 3 days' data on drinking water intake (n=3,476). We also eliminated subjects who were missing information on race (n=63), urbanization (n=1), weight (n=266), or education of the heads of household (n=5), all of which were variables chosen a priori for the analysis of variance models used to determine demographic categories for the Tables. In total we eliminated 4,289 subjects (13.9% of original sample) having incomplete data for one or more variables. The remaining subjects had complete data for all variables of interest and were virtually identical to the original sample distribution in age, sex, race, region, season of interview, urbanization, and education of heads of household.

### Stage 2 Calculating the Total Water, Intrinsic Water, and Indirect Tapwater Content of Foods and Beverages (Figure 2. Steps 5–10)

a. Relative Proportions (fraction) of Intrinsic Water and Indirect Tapwater in Foods and Beverages Consumed (Steps 5 and 6)
  Reviewing the description of each food and beverage reported as consumed in the 1977–78 NFCS (4,545 items) (Step 5), we assigned a value for the fraction of the water content (0% to 100%) that we estimated was derived from tapwater added during preparation (i.e., indirect tapwater) (Step 6). If the Food Code Description was not sufficiently clear, recipes from a standard cookbook (Rombauer and Becker, 1975) were consulted for quantities of water typically added during preparation of foods. Any other water in the food was considered "intrinsic" to the food as purchased in the market (i.e., intrinsic water, see Part II Definition of Terms). For each food recorded, the proportions of intrinsic water and indirect tapwater were calculated to total 100%.
  For example, because all of the water in a fresh peach is intrinsic to the food itself, the intrinsic water fraction was 100% and the indirect tapwater fraction assigned was 0%. Similarly, all of the water in a cup of hot tea is derived from the tap, thus the indirect tapwater fraction was 100% and the intrinsic water 0%.
  For a more complex example, the fraction of indirect tapwater in reconstituted frozen orange juice was calculated. Unreconstituted frozen orange juice contains by weight 42% (0.42) solids and 58% (0.58) water (U.S. Department of Agriculture, 1976–1986). The standard dilution is 1 volume frozen concentrate to 3 volumes water. Therefore, of the final 4-parts volume of reconstituted juice, 0.42/4.0 is solids (10%) and 3.58/4.0 (90%) is water. Of the 3.58 parts water, 0.58 (16%) is intrinsic water and 3.0 (84%) is indirect tapwater.
  The original Food Code Descriptions Files did not contain information on exact quantities of indirect tapwater added by study subjects during the preparation of foods. For most food items, therefore, we assigned a rounded estimate (0, 10, 25, 50, 75, 90, or 100%) to the indirect tapwater/intrinsic water fractions.
  For a small number of foods (for example, canned soups, frozen juices, evaporated milks), standard dilutions are widely used and more precise estimates could be made. Appendix C describes assumptions used in assigning the source of water in selected food groups and food items.
b. Total Water Content of Foods (Steps 7–8)
  The moisture (i.e., water) content of foods was not part of the original USDA Nutrient Database File (Step 7) and therefore was calculated by difference (i.e., by subtraction) for nearly all food items as follows (Step 8):
  W a t e r c o n t e n t ( g / 100 g f o o d ) = 100 - ((g total carbohydrate + g protein + g fat + g ash + g ethanol)/(100 g food))
  Total carbohydrate (including fiber), protein, and fat content values, but not ash (i.e., minerals), were already in the database.
  The ash values, rounded to the nearest 0.5%, were taken from the 1963 edition of USDA Handbook No. 8 (U.S. Department of Agriculture, 1963) as suggested by the staff of the Nutrient Data Research Branch, USDA (B. Perloff, personal communication). This edition of the Handbook was used because all food groups of interest were included and because ash values have changed but little in later editions (U.S. Department of Agriculture, 1976–1986).
  Several food items (for example, various pickles and freeze-dried coffee) had a very high content of nonnutritive elements such as salt or flavorings. Because the difference method would have yielded an erroneously high water content for these foods, we contacted the USDA for their directly determined water content values. (It would have been impractical to do this for all food items.) The water content of dried seaweed was obtained from the Japanese Food Composition tables (Japan, Science and Technology Agency, 1984).
  The ethanol content of alcoholic beverages was accounted for when calculating the water content of these items (Cotton, 1981; Rombauer and Becker, 1975).
c. Calculating the Intrinsic Water and Indirect Tapwater Content of Foods and Beverages (Steps 9 and 10)
  The total moisture content of each food item was multiplied by the indirect tapwater fraction and the intrinsic water fraction to yield separate values for the indirect tapwater and intrinsic water content of each food, expressed in grams per 100 grams wet weight (Step 9). The resulting merged variables were saved as an intermediate data file, Source and Content of Water in Foods (Step 10).

#### SPECIAL NOTE: Source of water in commercially prepared and home-prepared foods and beverages

Although a few foods were clearly labeled as "homemade" or "made from home recipe" while others (frozen entrees, carbonated soft drinks) clearly were commercially processed, the Food Code Descriptions File (Step 7) generally did not indicate where a food was prepared. When assigning the intrinsic water/indirect tapwater content of a food, we assumed that foods prepared in the subject’s community at a restaurant, workplace, or school were made with the same tapwater supply as was used by the subject at home. For example, all water used to make coffee was considered "indirect tapwater" regardless of where the coffee was drunk. It is unlikely that a restaurant would make coffee with bottled water rather than with the convenient and inexpensive tapwater already available. For discussion of ice, see Appendix C.

Conversely, we did not attempt to estimate quantities of "commercial water" added by a manufacturer during the processing of raw foods. All water in such processed foods and beverages was assigned as "intrinsic water," meaning that it would not have derived from the subject’s home supply or from a local tapwater supply.

For some foods both homemade and commercially prepared varieties were grouped together on the original data file. For these items, a "best guess" estimate was made as to the proportion which would have been home-prepared as opposed to commercially processed. For example, we estimated 50% of dry beans to be commercially canned and 50% to be home-cooked (see Appendix C for more details on these assumptions).

### Stage 3 Creating the Water Intake Database (Figure 2. Steps 11–25)

a. Introduction Variables from the two intermediate data files, Complete Subjects Food Intake File (Step 4), and Source and Content of Water in Foods File (Step 10), were used to create the final Water Intake Database File (Step 25).
b. Variable Set: Characteristics of Study Subjects
  1. Demographic Characteristics (Step 11) Demographic variables such as age, sex, residence (geographic region and urban/rural location), season of interview, race, and household educational level were transferred in a virtually unchanged format to the Water Intake Database.
  2. Weight (Steps 12, 16, and 17) Weight was converted from pounds, as reported by the subject, to kilograms (2.2 lb/kg) before addition to the Water Intake Database.
c. Variable Set: Direct Tapwater (Drinking Water) Intake (Steps 13, 18, and 19)
  The original Individual Food Intake File (Step 1) contained the questions "Did you drink any water on this day (other than in coffee, fruitade, etc.)?" and "If yes, about how many cups (8 fluid ounces)?" These were assumed to yield information on intake of drinking water, that is, water as a beverage. For each individual having complete data (Step 4) there was a separate value for the number of 8-fluid-ounce cups of water drunk on Day 1, Day 2, and Day 3 (Step 13). Using a rounded conversion figure of 240 grams per 8 fluid ounces, in accord with the USDA's gram-weight conversion figures for tea and coffee (U.S. Department of Agriculture, 1980), we multiplied the number of cups of water drunk by 240 g/cup (Step 18). This yielded the daily consumption of drinking water, expressed in grams per day (Step 19) (cups water drunk/day × 240 g/cup = drinking water g/day). We considered that all water deriving from the "cups of water" question was obtained from the household drinking water source (see Appendix C) and that all household drinking water was tapwater. We used the term "direct tapwater" to indicate tapwater drunk directly as a beverage as opposed to tapwater added to beverages and foods ("indirect tapwater").
  The interview did not inquire specifically about bottled drinking water. Unsweetened carbonated water such as, among others, club soda (Food Code 924101), was grouped with carbonated beverages rather than as a form of drinking water.
d. Variable Set: Intrinsic Water and Indirect Tapwater Intake (Steps 14, 15, 20, and 21)
  The data on quantities of foods and beverages consumed by study subjects (Step 14) and data on the intrinsic water and indirect tapwater contents of these food items (Step 15) were merged (Step 20) to yield quantities of intrinsic water and indirect tapwater consumed each day (Step 21).
e. Variables: Total Water and Tapwater Consumed (Steps 17, 21, 22, and 23) The daily intakes of direct tapwater (Step 19) and indirect tapwater (Step 21) were added to produce the estimate of tapwater drunk each day (Step 23). Subsequently, intrinsic water was added to tapwater (Step 22) to calculate the estimated Total Water Intake (Step 23). That is:
  - Direct Tapwater + Indirect Tapwater = Tapwater
  - Tapwater + Intrinsic Water = Total Water