# II TERMS AND ABBREVIATIONS USED

Term or Abbreviation | Definition
Added Tapwater | See “Tapwater, Indirect”
Age | Age at last birthday. Age of infants less than 1 year old was reported in months.
Age Group, Broad | The five broad age groupings (in years) are as follows: <1, 1–10, 11–19, 20–64, and 65+. Pregnant women, lactating women, and breast-fed children are not included in these groupings (also see Appendix F).
Age Group, Fine | The eleven fine age groupings (in years) are as follows: <0.5, 0.5–0.9, 1–3, 4–6, 7–10, 11–14, 15–19, 20–44, 45–64, 65–74, and 75+. Pregnant women, lactating women, and breast-fed children are not included in these groupings (also see Appendix F).
ANOVA | Analysis of variance
Biological Water | See “Water, Intrinsic”
Breast-fed Children | Infants or children receiving all or part of daily intake as human breast milk. Of the 100 nursing infants and children included in the analysis, 91 were less than 1 year old, 7 were 1 year old, and 2 were 2 years old.
Broad Age Group | See “Age Group, Broad”
Commercial Water | See “Water, Intrinsic”
Drinking Water | See “Tapwater, Direct”
Fine Age Group | See “Age Group, Fine”
Food-based Water | See “Water, Intrinsic”
Food Item | Food or beverage having a specific USDA 7-digit Food Code and Food Code Description (U.S. Department of Agriculture, 1980).
Indirect Tapwater | See “Tapwater, Indirect”
Lactating Women | Lactating women were identified as nursing a child 2 years old or less (U.S. Department of Agriculture, 1984).
NFCS | 1977–78 Nationwide Food Consumption Survey
nfs | “Not further specified,” refers to the descriptions of food and beverage items consumed in the Nationwide Food Consumption Survey.
Pregnant Women | Pregnant women were identified by the question “Are there any females in this household who are 4 months or more pregnant?” (U.S. Department of Agriculture, 1984).
Region | The four geographical regions include the following states (U.S. Department of Agriculture, 1984):
| Northeast -- Connecticut, Maine, Massachusetts, New Hampshire, New Jersey, New York, Pennsylvania, Rhode Island, Vermont;
| Midwest -- Illinois, Indiana, Iowa, Kansas, Michigan, Minnesota, Missouri, Nebraska, North Dakota, Ohio, South Dakota, Wisconsin;
| South -- Alabama, Arkansas, Delaware, District of Columbia, Florida, Georgia, Kentucky, Louisiana, Maryland, Mississippi, North Carolina, Oklahoma, South Carolina, Tennessee, Texas, Virginia, West Virginia;
| West -- Arizona, California, Colorado, Idaho, Montana, Nevada, New Mexico, Oregon, Utah, Washington, Wyoming.
Season | The four seasons during which interviews took place are composed of the following months:
| Spring -- April, May, and June;
| Summer -- July, August, and September;
| Fall -- October, November, and December;
| Winter -- January, February, and March.
Tapwater | All water from the household tap consumed directly as a beverage or used to prepare foods and beverages (see Figure 1). The sum of direct tapwater and indirect tapwater (see below).
Tapwater, Direct | Plain water consumed per se, that is, directly as a beverage. All water consumed as a beverage was assumed to come from a local source. Also called “drinkiner water” (see Figure 1). [underlined: Does] [underlined: not] include water-based beverages or carbonated bottled water.
Tapwater, Indirect | Tapwater used to prepare foods and beverages. Includes water-based beverages, such as tea and coffee (see Figure 1).
USDA | United States Department of Agriculture.
Water, Intrinsic | Water contained in (“intrinsic to”) foods and beverages at time of market purchase, before home or restaurant preparation (see Figure 1). Includes both the “biological water” of raw foods and any “commercial water” added during manufacturing or processing.
Water, Total | All water deriving from all sources including water intrinsic to foods and beverages (“intrinsic water”), tapwater consumed directly as a beverage (“direct tapwater”), and tapwater used in the preparation of foods and beverages (“indirect tapwater”) (see Figure 1).
Weight | Self-reported in pounds by the respondent. Pounds were converted to kilograms for this report.

FIGURE 1 DEFINITION OF WATER INTAKE TERMS