# I INTRODUCTION

Water, the universal biological solvent, is essential to life. Dietary surveys often neglect water because intake is assumed to meet or exceed requirements and because obtaining a thorough intake and usage history can be time-consuming and difficult. Water serves an important role as a vehicle not only for waterborne nutrients but also for toxic chemicals and microorganisms. Estimating exposure to substances in the water supply requires knowledge of the range of actual intake in exposed populations. Extremes of intake, as well as intake in the most susceptible population groups, are particularly pertinent for risk assessment and risk management. Total Water and Tapwater intake thus increasingly are topics of inquiry in epidemiologic research.

In this monograph, we present the first population-based estimates of quantity and sources of Tapwater and Total Water intake in the continental United States. These estimates are derived from dietary intake data from the 1977–78 Nationwide Food Consumption Survey. The Tables offer descriptive statistics and percentile distributions of Total Water and Tapwater intake from various dietary sources, including direct tapwater (i.e., drinking water).

We anticipate that these Tables will be used for a wide range of applications:

- Serving as comparison values to evaluate fluid consumption data collected for epidemiologic studies that measure the association between risk of disease and exposure to waterborne contaminants.
- Estimating variability in Tapwater and Total Water intake of "susceptible populations" (by virtue of age, sex, place of residence, and the like) to allow more informed discussion of risk management issues.
- Estimating the magnitude and variability of exposure to environmental contaminants such as lead or chlorinated hydrocarbons, or to minerals such as fluoride, calcium, magnesium, sodium (particularly in softened water), iron, copper, and trace elements in conjunction with data from direct analysis of water samples as well as information on water usage patterns. This is an important component of exposure assessment methodologies.
- Improving questionnaires and other survey instruments used in research on water intake by providing information about those dietary sources contributing the largest proportionate quantities of water.
- Evaluating whether an individual's water intake is unusually high or low compared to others of the same age and sex.