# APPENDIX F MEDIAN AND MEAN AGE OF STUDY SUBJECTS IN VARIOUS GROUPINGS

| AGE (years)
GROUPING | MEDIAN | MEAN | STANDARD DEVIATION | RANGE
Pregnant Women | 25 | 25.5 | 5.6 | 15–49
Lactating Women | 27 | 27.1 | 4.8 | 17–40
Breast-fed Children^1^ | 0.3 | 0.4 | 0.3 | .04–2
Broad Age Grouping^1,2^ (years)
< 1 | 0.5 | 0.5 | 0.3 | *
1–10 | 6 | 6 | 3 | *
11–19 | 15 | 15 | 3 | *
20–64 | 38 | 40 | 13 | *
65+ | 71 | 73 | 6 | *
Fine Age Grouping^1,2^ (years)
< 0.5 | 0.3 | 0.2 | 0.1 | *
0.5– 0.9 | 0.7 | 0.7 | 0.1 | *
1– 3 | 2 | 2 | 1 | *
4– 6 | 5 | 5 | 1 | *
7–10 | 9 | 9 | 1 | *
11–14 | 13 | 13 | 1 | *
15–19 | 17 | 17 | 1 | *
20–44 | 30 | 31 | 7 | *
45–64 | 54 | 54 | 6 | *
65–74 | 69 | 69 | 3 | *
75+ | 79 | 80 | 4 | *
All Ages^1,2^ | 30 | 33 | 22 | .04–97

1 Males and females combined.

2 Does not include pregnant women, lactating women, and breast-fed children.

* Self-defining.