# APPENDIX E SEX, AGE, AND RACE DISTRIBUTION OF STUDY SAMPLE AND 1977 U.S. POPULATION^1,2^

| STUDY SUBJECTS ANALYZED | | | | U.S. POPULATION
| UNWEIGHTED COUNT^3^ | | WEIGHTED COUNT^4^ | | (1977 ESTIMATED)
| n | % | n | % | N (thousands) | %
Sex
Male | 11930 | 45.1 | 17722.1 | 44.2 | 105240 | 48.6
Female | 14516 | 54.9 | 22387.8 | 55.8 | 111092 | 51.4
Total | 26446 | 100.0 | 40109.9 | 100.0 | 216332 | 100.0
Age (years)
<20 | 11909 | 45.0 | 13744.1 | 34.2 | 72710 | 33.6
20–44 | 7436 | 28.1 | 13923.2 | 34.7 | 76351 | 35.3
45–64 | 4560 | 17.2 | 8300.4 | 20.7 | 43778 | 20.2
65–74 | 1663 | 6.3 | 2740.2 | 6.8 | 14583 | 6.7
75+ | 878 | 3.3 | 1401.8 | 3.5 | 8910 | 4.1
Total | 26446 | 99.9 | 40109.7 | 99.9 | 216332 | 99.9
Race
White | 22097 | 83.6 | 33385.9 | 83.2 | 187365 | 86.6
Black | 3395 | 12.8 | 5164.9 | 12.9 | 25112 | 11.6
Other | 954 | 3.6 | 1559.1 | 3.9 | 3855 | 1.8
Total | 26446 | 100.0 | 40109.9 | 100.0 | 216332 | 100.0

3 Study subjects with complete data. Outliers excluded. Breast-fed children, pregnant women, and lactating women included (see Section IV-B).

4 See Section IV-E for a description of weighting factors.

1 Estimated 1977 U.S. population-distribution is based on figures from U.S. Census Bureau (National Cancer Institute, 1981).

2 Values may not add up to total due to rounding.